# SOURCES AND METHODS

## Unit of Analysis

The unit of analysis is the hospital stay rather than the patient. All discharges have been weighted to produce national estimates.

## Coding Diagnoses and Procedures

Diagnoses and procedures associated with an inpatient hospitalization can be defined using several different medical condition classification systems. The Clinical Classifications Software (CCS) was used predominantly within this report to identify specific diagnoses and procedures. CCS is based on the International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM), a uniform and standardized coding system containing over 13,600 diagnosis codes and 3,700 procedure codes. Each discharge record in the NIS is associated with one or more ICD-9-CM diagnosis code(s) and may contain one or more ICD-9-CM procedure code(s) if a procedure was performed during that hospitalization. Each hospital stay can have multiple CCS diagnoses and multiple CCS procedures.

In the CCS, ICD-9-CM codes are clustered into a smaller number of clinically meaningful categories that are sometimes more useful for presenting descriptive statistics than are individual ICD-9-CM codes. CCS codes are used extensively in this report to define groups of diagnoses and procedures for analysis. The CCS codes allow the reader to quickly and easily recognize patterns and trends in broad categories of hospital utilization. More information on CCS can be found online (http://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp). Specific CCS conditions or diagnoses can also be summarized into CCS body system or condition categories, which are broad groups of CCS conditions, such as Neoplasms, Mental Disorders, and Diseases of the Circulatory System.

## Exhibit Diagnoses and Procedures

Throughout this report, combinations of diagnostic and procedure codes are used to isolate specific conditions or procedures. These codes are defined below by exhibit number.

### SECTION 1 OVERVIEW STATISTICS FOR INPATIENT HOSPITAL STAYS

#### EXHIBIT 1.3

Principal CCS by body system or condition categories are summarized from specific CCS conditions using the multilevel CCS tool (http://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp). Mental health and substance abuse conditions are identified using the CCS-MHSA tool (http://www.hcup-us.ahrq.gov/toolssoftware/mhsa/mhsa.jsp). (For more information on the ICD-9-CM codes that comprise each CCS, refer to http://www.hcup-us.ahrq.gov/toolssoftware/ccs/AppendixASingleDX.txt for diagnoses and http://www.hcup-us.ahrq.gov/toolssoftware/ccs/AppendixBSinglePR.txt for procedures.) The body system or condition category, CCS code and category name are listed below.

CATEGORY | CCS CONDITION DESCRIPTION
1 | INFECTIOUS AND PARASITIC DISEASE
1 | 1 | Tuberculosis
1 | 2 | Septicemia (except in labor)
1 | 3 | Bacterial infection; unspecified site
1 | 4 | Mycoses
1 | 5 | HIV infection
1 | 6 | Hepatitis
1 | 7 | Viral infection
1 | 8 | Other infections; including parasitic
1 | 9 | Sexually transmitted infections (not HIV or hepatitis)
1 | 10 | Immunizations and screening for infectious disease
2 | NEOPLASMS
2 | 11 | Cancer of head and neck
2 | 12 | Cancer of esophagus
2 | 13 | Cancer of stomach
2 | 14 | Cancer of colon
2 | 15 | Cancer of rectum and anus
2 | 16 | Cancer of liver and intrahepatic bile duct
2 | 17 | Cancer of pancreas
2 | 18 | Cancer of other GI organs; peritoneum
2 | 19 | Cancer of bronchus; lung
2 | 20 | Cancer; other respiratory and intrathoracic
2 | 21 | Cancer of bone and connective tissue
2 | 22 | Melanomas of skin
2 | 23 | Other non-epithelial cancer of skin
2 | 24 | Cancer of breast
2 | 25 | Cancer of uterus
2 | 26 | Cancer of cervix
2 | 27 | Cancer of ovary
2 | 28 | Cancer of other female genital organs
2 | 29 | Cancer of prostate
2 | 30 | Cancer of testis
2 | 31 | Cancer of other male genital organs
2 | 32 | Cancer of bladder
2 | 33 | Cancer of kidney and renal pelvis
2 | 34 | Cancer of other urinary organs
2 | 35 | Cancer of brain and nervous system
2 | 36 | Cancer of thyroid
2 | 37 | Hodgkin’s disease
2 | 38 | Non-Hodgkin’s lymphoma
2 | 39 | Leukemias
2 | 40 | Multiple myeloma
2 | 41 | Cancer; other and unspecified primary
2 | 42 | Secondary malignancies
2 | 43 | Malignant neoplasm without specification of site
2 | 44 | Neoplasms of unspecified nature or uncertain behavior
2 | 45 | Maintenance chemotherapy; radiotherapy
2 | 46 | Benign neoplasm of uterus
2 | 47 | Other and unspecified benign neoplasm
3 | ENDOCRINE, NUTRITIONAL, AND OTHER METABOLIC DISEASES AND IMMUNITY DISORDERS
3 | 48 | Thyroid disorders
3 | 49 | Diabetes mellitus without complication
3 | 50 | Diabetes mellitus with complications
3 | 51 | Other endocrine disorders
3 | 52 | Nutritional deficiencies
3 | 53 | Disorders of lipid metabolism
3 | 54 | Gout and other crystal arthropathies
3 | 55 | Fluid and electrolyte disorders
3 | 56 | Cystic fibrosis
3 | 57 | Immunity disorders
3 | 58 | Other nutritional; endocrine; and metabolic disorders
4 | DISEASES OF THE BLOOD AND BLOOD FORMING ORGANS
4 | 59 | Deficiency and other anemia
4 | 60 | Acute posthemorrhagic anemia
4 | 61 | Sickle cell anemia
4 | 62 | Coagulation and hemorrhagic disorders
4 | 63 | Diseases of white blood cells
4 | 64 | Other hematologic conditions
5 | MENTAL DISORDERS
5 | 650 | MHSA: Adjustment disorders
5 | 651 | MHSA: Anxiety disorders
5 | 652 | MHSA: Attention-deficit, conduct, and disruptive behavior disorders
5 | 653 | MHSA: Delirium, dementia, and amnestic and other cognitive disorders
5 | 654 | MHSA: Developmental disorders
5 | 655 | MHSA: Disorders usually diagnosed in infancy, childhood, or adolescence
5 | 656 | MHSA: Impulse control disorders, NEC
5 | 657 | MHSA: Mood disorders
5 | 658 | MHSA: Personality disorders
5 | 659 | MHSA: Schizophrenia and other psychotic disorders
5 | 660 | MHSA: Alcohol-related disorders
5 | 661 | MHSA: Substance-related disorders
5 | 662 | MHSA: Suicide and intentional self-inflicted injury
5 | 663 | MHSA: Screening and history of mental health and substance abuse code
5 | 670 | MHSA: Miscellaneous mental disorders
6 | DISEASES OF THE NERVOUS SYSTEM AND SENSE ORGANS
6 | 76 | Meningitis (except that caused by tuberculosis or sexually transmitted disease)
6 | 77 | Encephalitis (except that caused by tuberculosis or sexually transmitted disease)
6 | 78 | Other CNS infection and poliomyelitis
6 | 79 | Parkinson’s disease
6 | 80 | Multiple sclerosis
6 | 81 | Other hereditary and degenerative nervous system conditions
6 | 82 | Paralysis
6 | 83 | Epilepsy; convulsions
6 | 84 | Headache; including migraine
6 | 85 | Coma; stupor; and brain damage
6 | 86 | Cataract
6 | 87 | Retinal detachments; defects; vascular occlusion; and retinopathy
6 | 88 | Glaucoma
6 | 89 | Blindness and vision defects
6 | 90 | Inflammation; infection of eye (except that caused by tuberculosis or transmitted disease)
6 | 91 | Other eye disorders
6 | 92 | Otitis media and related conditions
6 | 93 | Conditions associated with dizziness or vertigo
6 | 94 | Other ear and sense organ disorders
6 | 95 | Other nervous system disorders
7 | DISEASES OF THE CIRCULATORY SYSTEM
7 | 96 | Heart valve disorders
7 | 97 | Peri-; endo-; and myocarditis; cardiomyopathy (except that caused by tuberculosis or sexually transmitted disease)
7 | 98 | Essential hypertension
7 | 99 | Hypertension with complications and secondary hypertension
7 | 100 | Acute myocardial infarction
7 | 101 | Coronary atherosclerosis and other heart disease
7 | 102 | Nonspecific chest pain
7 | 103 | Pulmonary heart disease
7 | 104 | Other and ill-defined heart disease
7 | 105 | Conduction disorders
7 | 106 | Cardiac dysrhythmias
7 | 107 | Cardiac arrest and ventricular fibrillation
7 | 108 | Congestive heart failure; nonhypertensive
7 | 109 | Acute cerebrovascular disease
7 | 110 | Occlusion or stenosis of precerebral arteries
7 | 111 | Other and ill-defined cerebrovascular disease
7 | 112 | Transient cerebral ischemia
7 | 113 | Late effects of cerebrovascular disease
7 | 114 | Peripheral and visceral atherosclerosis
7 | 115 | Aortic; peripheral; and visceral artery aneurysms
7 | 116 | Aortic and peripheral arterial embolism or thrombosis
7 | 117 | Other circulatory disease
7 | 118 | Phlebitis; thrombophlebitis and thromboembolism
7 | 119 | Varicose veins of lower extremity
7 | 120 | Hemorrhoids
7 | 121 | Other diseases of veins and lymphatics
8 | DISEASES OF THE RESPIRATORY SYSTEM
8 | 122 | Pneumonia (except that caused by tuberculosis or sexually transmitted disease)
8 | 123 | Influenza
8 | 124 | Acute and chronic tonsillitis
8 | 125 | Acute bronchitis
8 | 126 | Other upper respiratory infections
8 | 127 | Chronic obstructive pulmonary disease and bronchiectasis
8 | 128 | Asthma
8 | 129 | Aspiration pneumonitis; food/vomitus
8 | 130 | Pleurisy; pneumothorax; pulmonary collapse
8 | 131 | Respiratory failure; insufficiency; arrest (adult)
8 | 132 | Lung disease due to external agents
8 | 133 | Other lower respiratory disease
8 | 134 | Other upper respiratory disease
9 | DISEASES OF THE DIGESTIVE SYSTEM
9 | 135 | Intestinal infection
9 | 136 | Disorders of teeth and jaw
9 | 137 | Diseases of mouth; excluding dental
9 | 138 | Esophageal disorders
9 | 139 | Gastroduodenal ulcer (except hemorrhage)
9 | 140 | Gastritis and duodenitis
9 | 141 | Other disorders of stomach and duodenum
9 | 142 | Appendicitis and other appendiceal conditions
9 | 143 | Abdominal hernia
9 | 144 | Regional enteritis and ulcerative colitis
9 | 145 | Intestinal obstruction without hernia
9 | 146 | Diverticulosis and diverticulitis
9 | 147 | Anal and rectal conditions
9 | 148 | Peritonitis and intestinal abscess
9 | 149 | Biliary tract disease
9 | 151 | Other liver diseases
9 | 152 | Pancreatic disorders (not diabetes)
9 | 153 | Gastrointestinal hemorrhage
9 | 154 | Noninfectious gastroenteritis
9 | 155 | Other gastrointestinal disorders
10 | DISEASES OF THE GENITOURINARY SYSTEM
10 | 156 | Nephritis; nephrosis; renal sclerosis
10 | 157 | Acute and unspecified renal failure
10 | 158 | Chronic renal failure
10 | 159 | Urinary tract infections
10 | 160 | Calculus of urinary tract
10 | 161 | Other diseases of kidney and ureters
10 | 162 | Other diseases of bladder and urethra
10 | 163 | Genitourinary symptoms and ill-defined conditions
10 | 164 | Hyperplasia of prostate
10 | 165 | Inflammatory conditions of male genital organs
10 | 166 | Other male genital disorders
10 | 167 | Nonmalignant breast conditions
10 | 168 | Inflammatory diseases of female pelvic organs
10 | 169 | Endometriosis
10 | 170 | Prolapse of female genital organs
10 | 171 | Menstrual disorders
10 | 172 | Ovarian cyst
10 | 173 | Menopausal disorders
10 | 174 | Female infertility
10 | 175 | Other female genital disorders
11 | COMPLICATIONS OF CHILDBIRTH, PREGNANCY, AND THE PUERPERIUM
11 | 176 | Contraceptive and procreative management
11 | 177 | Spontaneous abortion
11 | 178 | Induced abortion
11 | 179 | Post abortion complications
11 | 180 | Ectopic pregnancy
11 | 181 | Other complications of pregnancy
11 | 182 | Hemorrhage during pregnancy; abruptio placenta; placenta previa
11 | 183 | Hypertension complicating pregnancy; childbirth and the puerperium
11 | 184 | Early or threatened labor
11 | 185 | Prolonged pregnancy
11 | 186 | Diabetes or abnormal glucose tolerance complicating pregnancy; childbirth; or the puerperium
11 | 187 | Malposition; malpresentation
11 | 188 | Fetopelvic disproportion; obstruction
11 | 189 | Previous C-section
11 | 190 | Fetal distress and abnormal forces of labor
11 | 191 | Polyhydramnios and other problems of amniotic cavity
11 | 192 | Umbilical cord complication
11 | 193 | OB-related trauma to perineum and vulva
11 | 194 | Forceps delivery
11 | 195 | Other complications of birth; puerperium affecting management of mother
11 | 196 | Normal pregnancy and/or delivery
12 | DISEASES OF THE SKIN AND SUBCUTANEOUS TISSUE
12 | 197 | Skin and subcutaneous tissue infections
12 | 198 | Other inflammatory condition of skin
12 | 199 | Chronic ulcer of skin
12 | 200 | Other skin disorders
13 | DISEASES OF THE MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE.
13 | 201 | Diabetes or abnormal glucose tolerance complicating pregnancy; childbirth; or the puerperium
13 | 202 | Rheumatoid arthritis and related disease
13 | 203 | Osteoarthritis
13 | 204 | Other non-traumatic joint disorders
13 | 205 | Spondylosis; intervertebral disc disorders; other back problems
13 | 206 | Osteoporosis
13 | 207 | Pathological fracture
13 | 208 | Acquired foot deformities
13 | 209 | Other acquired deformities
13 | 210 | Systemic lupus erythematosus and connective tissue disorders
13 | 211 | Other connective tissue disease
13 | 212 | Other bone disease and musculoskeletal deformities
14 | CONGENITAL ANOMALIES
14 | 213 | Cardiac and circulatory congenital anomalies
14 | 214 | Digestive congenital anomalies
14 | 215 | Genitourinary congenital anomalies
14 | 216 | Nervous system congenital anomalies
14 | 217 | Other congenital anomalies
15 | CERTAIN CONDITIONS ORIGINATING IN THE PERINATAL PERIOD
15 | 218 | Liveborn
15 | 219 | Short gestation; low birth weight; and fetal growth retardation
15 | 220 | Intrauterine hypoxia and birth asphyxia
15 | 221 | Respiratory distress syndrome
15 | 222 | Hemolytic jaundice and perinatal jaundice
15 | 223 | Birth trauma
15 | 224 | Other perinatal conditions
16 | INJURIES AND POISONINGS
16 | 225 | Joint disorders and dislocations; trauma-related
16 | 226 | Fracture of neck of femur (hip)
16 | 227 | Spinal cord injury
16 | 228 | Skull and face fractures
16 | 229 | Fracture of upper limb
16 | 230 | Fracture of lower limb
16 | 231 | Other fractures
16 | 232 | Sprains and strains
16 | 233 | Intracranial injury
16 | 234 | Crushing injury or internal injury
16 | 235 | Open wounds of head; neck; and trunk
16 | 236 | Open wounds of extremities
16 | 237 | Complication of device; implant or graft
16 | 238 | Complications of surgical procedures or medical care
16 | 239 | Superficial injury; contusion
16 | 240 | Burns
16 | 241 | Poisoning by psychotropic agents
16 | 242 | Poisoning by other medications and drugs
16 | 243 | Poisoning by nonmedicinal substances
16 | 244 | Other injuries and conditions due to external causes
17 | OTHER CONDITIONS
17 | 245 | Syncope
17 | 246 | Fever of unknown origin
17 | 247 | Lymphadenitis
17 | 248 | Gangrene
17 | 249 | Shock
17 | 250 | Nausea and vomiting
17 | 251 | Abdominal pain
17 | 252 | Malaise and fatigue
17 | 253 | Allergic reactions
17 | 254 | Rehabilitation care; fitting of prostheses; and adjustment of devices
17 | 255 | Administrative/social admission
17 | 256 | Medical examination/evaluation
17 | 257 | Other aftercare
17 | 258 | Other screening for suspected conditions (not mental disorders or infectious disease)

### SECTION 2 INPATIENT HOSPITAL STAYS BY DIAGNOSIS

#### EXHIBIT 2.1

Chronic conditions were identified using the Chronic Conditions Indicator, an HCUP tool used to categorize ICD-9-CM diagnosis codes into one of two categories: chronic or not chronic (acute). Diagnosis codes for this tool are based on the International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM), Fifth Edition. Additional information can be found at http://www.hcup-us.ahrq.gov/toolssoftware/chronic/chronic/chronic.jsp. Maternal CCS categories not listed on the exhibit table but included in total maternal discharges:

CCS | CONDITION DESCRIPTION
176 | Contraceptive and procreative management (birth control or helping with conception)
177 | Spontaneous abortion
178 | Induced abortion
179 | Postabortion complications (complications following abortion)
180 | Ectopic pregnancy (abdominal or tubal pregnancy)
181 | Other complications of pregnancy
182 | Hemorrhage during pregnancy, abruptio placenta, placenta previa (bleeding and placenta disorders during pregnancy)
186 | Diabetes or abnormal glucose tolerance complicating pregnancy, childbirth, or the puerperium (diabetes or high blood glucose during pregnancy)
187 | Malposition, malpresentation (breech birth and other disorders of baby’s position during birth)
188 | Obstructed labor or fetopelvic disproportion
194 | Forceps delivery
195 | Other maternal complications of birth, puerperium affecting management of mother (other maternal complications of birth and period after childbirth)

Infant CCS categories not listed on the exhibit table but included in total maternal discharges:

CCS | CONDITION DESCRIPTION
218 | Liveborn
219 | Short gestation, low birth weight, and fetal growth retardation
220 | Intrauterine hypoxia and birth asphyxia
221 | Respiratory distress syndrome
222 | Hemolytic jaundice and perinatal jaundice
223 | Birth trauma
224 | Other perinatal conditions

#### EXHIBIT 2.4

Comorbidities were defined using the Comorbidity software, an HCUP tool that assigns variables that identify comorbidities in hospital discharge records using the diagnosis coding of ICD-9-CM (International Classification of Diseases, Ninth Edition, Clinical Modifications). For more information, see http://www.hcup-us.ahrq.gov/toolssoftware/comorbidity/comorbidity.jsp.

### SECTION 3 INPATIENT HOSPITAL STAYS BY PROCEDURE

#### EXHIBIT 3.1

Two steps were used to define maternal and infant procedures. First, all maternal and newborn stays were identified using the following codes:

Maternal stays were identified using the Major Diagnostic Code 14: Pregnancy, childbirth and the puerperium.

Newborn stays were identified using the following CCS diagnostic codes:

CCS | CONDITION DESCRIPTION
218 | Liveborn
219 | Short gestation, low birth weight, and fetal growth retardation
220 | Intrauterine hypoxia and birth asphyxia (lack of oxygen to baby in uterus or during birth)
221 | Respiratory distress syndrome
222 | Hemolytic jaundice and perinatal jaundice
223 | Birth trauma
224 | Other perinatal conditions (other conditions occurring around the time of birth)

Second, maternal and newborn stays were examined for the following CCS all-listed procedures that were typically associated with maternal and infant stays:

Maternal procedures:

CCS | PROCEDURE DESCRIPTION
133 | Episiotomy (surgical incision into the perineum and vagina to prevent traumatic tearing during delivery)
134 | Cesarean section
135 | Forceps, vacuum, and breech delivery
136 | Artificial rupture of membranes to assist delivery
137 | Other procedures to assist delivery
138 | Diagnostic amniocentesis (diagnostic sampling of the fluid in the amniotic sac)
139 | Fetal monitoring
140 | Repair of obstetric laceration
141 | Other therapeutic obstetrical procedures

Infant procedures:

CCS | PROCEDURE DESCRIPTION
115 | Circumcision
220 | Ophthalmologic and otologic diagnosis and treatment (vision and hearing diagnosis and treatment)
228 | Prophylactic vaccinations and inoculations

### SECTION 4 SPENDING FOR INPATIENT HOSPITAL STAYS

#### EXHIBIT 4.1

See definition for CCS Body System and Condition Categories under Exhibit 1.3 above.

### SECTION 5 PAYERS FOR INPATIENT HOSPITAL STAYS

#### EXHIBIT 5.5

See definition of maternal stays under Exhibit 3.1 above.

#### EXHIBIT 5.8 and 5.9

See definition for CCS Body System and Condition Categories under Exhibit 1.3 above.