# 2 INPATIENT HOSPITAL STAYS BY DIAGNOSIS

## HIGHLIGHTS

- Conditions related to pregnancy and childbirth were the reason for more than 1 out of every 5 female hospitalizations in 2007. When combined with stays for newborn infants, these hospitalizations accounted for one-quarter of all male and female stays.
  - Maternal discharges increased to 5.0 million in 2007, a 16-percent increase since 1997.
  - Previous C-sections increased 107 percent between 1997 and 2007.
  - Stays with high blood pressure during pregnancy increased by 28 percent between 1997 and 2007.
  - Stays with umbilical cord complications declined by 15 percent.
  - Infant hospitalizations increased to 4.7 million in 2007, a 21-percent increase since 1997.
- Circulatory conditions were the most frequent major cause of hospital stays in 2007, accounting for 16 percent of all discharges. Five circulatory conditions were among the top 10 most frequent principal diagnoses in 2007.
  - Stays for non-specific chest pain increased by 47 percent between 1997 and 2007 while those for irregular heart beat increased by 28 percent.
  - Stays for coronary artery disease declined 31 percent and for heart attack by 15 percent.
  - Stays for congestive heart failure changed very little from 1997 to 2007.
  - Ranking 6th in 1997, hospital stays for acute cerebrovascular disease dropped to 15th in 2007 as stays declined 14 percent.
- Several frequently occurring infections were among the most rapidly increasing reasons for hospitalizations between 1997 and 2007.
  - Stays for skin and subcutaneous tissue infections rose 90 percent for men and 75 percent for women.
  - Septicemia increased by 63 percent—up 77 percent among men and 53 percent among women.
  - Among adults 85 and over, septicemia (up 64 percent) and urinary tract infections (up 58 percent) increased at more than twice the rate of all hospitalizations for this age group.
- Several conditions were common among children and young adults.
  - Asthma, the most common reason for hospital admission among children 1–17, declined by 28 percent between 1997 and 2007.
  - Appendicitis, another common reason for hospital stays for children 1–17, accounted for 5 percent of discharges in this age group in 2007, increasing by 20 percent between 1997 and 2007.
  - Depression and bipolar disorders (mood disorders), among the most common diagnoses for children and young adults, increased 27 percent for children 1–17 and 15 percent for adults 18–44 between 1997 and 2007. Among all ages, mood disorders grew by 32 percent for men and by 13 percent for women over the same period.
- Degenerative joint disease (osteoarthritis) increased 95 percent over the 1997–2007 period. This condition caused many more hospitalizations for females (498,000 discharges) than for males (314,000 discharges) in 2007.
- Hypertension was a comorbidity in 35 percent of all hospital stays in 2007, diabetes in 17 percent of stays, depression in 7 percent stays, and alcohol abuse, drug abuse, and/or psychoses each in 3 percent of stays.
- Chronic conditions were a principal or secondary diagnosis for 74 percent of all hospital stays in 2007.

## EXHIBIT 2.1 Most Frequent Principal Diagnoses

Number of Discharges, Percent Distribution, Rank, and Growth of the Most Frequent Principal CCS Diagnoses for Inpatient Hospital Stays, 1997 and 2007

PRINCIPAL CCS DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | | PERCENT OF DISCHARGES | | RANK 1 | | CUMULATIVE GROWTH
PRINCIPAL CCS DIAGNOSIS | 1997 | 2007 | 1997 | 2007 | 1997 | 2007 | 1997–2007
All discharges | 34,679 | 39,542 | 100.0% | 100.0% | — | — | 14%
Chronic conditions^†^ | 13,778 | 14,447^‡^ | 39.7 | 36.5 | — | — | 5
Pregnancy, childbirth, and newborn infants | 8,236 | 9,732 | 23.7 | 24.6 | — | — | 18
All maternal discharges^*^ | 4,338 | 5,031 | 12.5 | 12.7 | — | — | 16
Trauma to external female genitals (vulva) and area between anus and vagina (perineum) due to childbirth | 713 | 868 | 2.1 | 2.2 | — | — | 22
Previous C-section | 271 | 562 | 0.8 | 1.4 | — | — | 107
Normal pregnancy and/or delivery | 544 | 312 | 1.6 | 0.8 | — | — | −43
Prolonged pregnancy | § | 276 | § | 0.7 | — | — | §
Fetal distress and abnormal forces of labor | § | 246 | § | 0.6 | — | — | §
Hypertension complicating pregnancy, childbirth and the puerperium (high blood pressure during pregnancy) | 185 | 238 | 0.5 | 0.6 | — | — | 28
Early or threatened labor | 261 | 235^‡^ | 0.8 | 0.6 | — | — | −10
Umbilical cord complication | 259 | 219 | 0.7 | 0.6 | — | — | −15
Polyhydramnios and other problems of amniotic cavity (excess amniotic fluid and other problems of amniotic cavity) | 202 | 209^‡^ | 0.6 | 0.5 | — | — | 3
All infant discharges | 3,898 | 4,701 | 11.2 | 11.9 | — | — | 21
Pneumonia | 1,232 | 1,172 | 3.6 | 3.0 | 2 | 1 | −5
Congestive heart failure | 991 | 1,025^‡^ | 2.9 | 2.6 | 3 | 2 | 3
Coronary atherosclerosis (coronary artery disease) | 1,407 | 964 | 4.1 | 2.4 | 1 | 3 | −31
Osteoarthritis (degenerative joint disease) | 418 | 815 | 1.2 | 2.1 | 15 | 4 | 95
Non-specific chest pain | 538 | 788 | 1.6 | 2.0 | 9 | 5 | 47
Mood disorders (depression and bipolar disorder) | 641 | 774 | 1.8 | 2.0 | 5 | 6 | 21
Cardiac dysrhythmias (irregular heart beat) | 572 | 731 | 1.7 | 1.8 | 7 | 7 | 28
Septicemia (blood infection) | 413 | 675 | 1.2 | 1.7 | 16 | 8 | 63
Disorders of intervertebral discs and bones in spinal column (back problems) | 536 | 634 | 1.5 | 1.6 | 10 | 9 | 18
Acute myocardial infarction (heart attack) | 732 | 625 | 2.1 | 1.6 | 4 | 10 | −15
Acute cerebrovascular disease | 616 | 527 | 1.8 | 1.3 | 6 | 15 | −14
Chronic obstructive pulmonary disease and bronchiectasis | 551 | 593 | 1.6 | 1.5 | 8 | 13 | 8

1 Rankings for principal diagnoses other than pregnancy, childbirth or newborn infant.

— Rank not applicable.

† Includes the number of discharges with a principal diagnosis that is considered to be a chronic condition.

‡ 2007 discharges are [underlined: not] statistically different from 1997 discharges at p<0.05.

* Includes additional maternal CCS diagnoses not shown on this table but listed in the Sources and Methods of this report.

§ Consistent data are not available for this diagnosis due to coding changes that took place between 1997 and 2007.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2007.

In 2007, there were 39.5 million hospital stays, an increase of 14 percent since 1997. Trends in these stays are displayed for chronic conditions, for pregnancy, childbirth and newborn infants, and for specific other conditions.

Chronic conditions:

- Chronic conditions were the main reason for 40 percent of all hospitalizations in 1997 and for 37 percent in 2007.
- The number of discharges with principal chronic condition diagnoses remained relatively stable between 1997 and 2007, despite the growth in discharges overall (up 14 percent).

Pregnancy, childbirth, and newborn infants:

- Conditions related to pregnancy, childbirth, and newborn infants were by far the most frequent reasons for hospitalization, accounting for 25 percent of discharges (nearly one in four) in 2007.
- There were 5.0 million maternal discharges in 2007, a 16-percent increase since 1997. Not all of these maternal discharges involved the birth of an infant; some dealt with complications during pregnancy.
  - The most common principal diagnosis among maternal discharges was trauma to external female genitals during childbirth, which increased 22 percent between 1997 and 2007.
  - Stays for normal pregnancy declined by 43 percent from 1997 to 2007. More maternal stays in 2007 had a principal diagnosis that indicated some problem in pregnancy or delivery than in 1997.
  - In contrast, the principal diagnosis of previous C-section increased 107 percent between 1997 and 2007.
  - Stays with a principal diagnosis of high blood pressure during pregnancy increased by 28 percent between 1997 and 2007.
  - Stays with a principal diagnosis of umbilical cord complications declined by 15 percent.
- There were 4.7 million infant discharges in 2007, a 21-percent increase since 1997.

CCS principal diagnoses:

- The 10 most frequently occurring principal diagnoses outside of pregnancy, childbirth and newborn infants accounted for about one-fifth of all discharges in 2007.
  - Pneumonia (3.0 percent of all discharges) and congestive heart failure (2.6 percent) were the most common principal diagnoses.
  - Two of the 10 most frequent principal diagnoses in 2007 were not among the most frequent diagnoses in 1997, but were added to the list because of their rapid growth. Stays for treatment of osteoarthritis (degenerative joint disease) increased 95 percent over the 1997–2007 period. Similarly, septicemia discharges increased by 63 percent.
- Five circulatory diseases—congestive heart failure, coronary artery disease, non-specific chest pain, irregular heartbeat, and acute myocardial infarction (heart attack)—were among the top 10 most frequent principal diagnoses in 2007.
  - Stays for non-specific chest pain increased 47 percent between 1997 and 2007 while those for irregular heart beat increased 28 percent. Stays for coronary artery disease declined 31 percent and for heart attack by 15 percent. Stays for congestive heart failure changed very little from 1997 to 2007.
- Two conditions were among the top 10 in 1997, but were not among the top 10 conditions in 2007.
  - Hospital stays for acute cerebrovascular disease declined 14 percent. This condition ranked 6th in 1997, but dropped to 15th by 2007.
  - Chronic obstructive pulmonary disease ranked 8th among the most common conditions in 1997. Discharges with this diagnosis increased by 42,000 between 1997 and 2007, but still dropped in rank to 13th.

Distribution of Discharges by Type of Principal and Secondary Conditions, 2007

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2007.

A chronic condition is defined as a condition that lasts 12 months or longer and limits an individual’s self-care, independent living, and social interactions or results in the need for ongoing intervention with medical products, services, and special equipment.^1^ More than 40 percent of the non-institutionalized population has at least one chronic condition—a share that has risen over time, particularly in the mid to older age population.^2^ The incidence of chronic conditions and the ability to manage these conditions in an outpatient setting will determine the extent to which chronic conditions are the cause or contributing diagnosis for hospital stays.

- Chronic conditions^3^ were a principal or secondary diagnosis for 74 percent of all hospital stays in 2007.
  - Thirty-seven percent of all discharges had a principal chronic condition.
  - Another 38 percent of all discharges had a secondary chronic condition that could complicate treatment and recovery for an acute condition (the reason for the hospital stay).
- Hospital stays with no mention of a chronic condition on the discharge record accounted for just 26 percent of all stays.

Growth of Discharges by Type of Principal and Secondary Conditions, 1997–2007

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2007.

Increasingly in recent years, persons with chronic conditions have difficulty paying for care, which can result in hospitalizations when care is delayed and medicines are not purchased because of concerns about cost.^4^

- Hospital stays for principal non-chronic conditions with a noted secondary chronic condition grew by 42 percent between 1997 and 2007.
- During the same period, hospital stays with a principal chronic condition or with no mention of chronic conditions remained relatively unchanged.
- There are a number of possible reasons why the growth in discharges with secondary chronic conditions is outpacing other discharge types, including increased reporting of secondary chronic conditions and a rise in the incidence of chronic conditions.

## EXHIBIT 2.2 Most Frequent Principal Diagnoses by Age

Number of Discharges, Percent Distribution, and Growth of the Most Frequent Principal CCS Diagnoses for Inpatient Hospital Stays by Age, 1997 and 2007

AGE GROUP AND PRINCIPAL CCS DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | | PERCENT OF AGE-SPECIFIC TOTAL DISCHARGES | | CUMULATIVE GROWTH
AGE GROUP AND PRINCIPAL CCS DIAGNOSIS | 1997 | 2007 | 1997 | 2007 | 1997–2007
All ages, total discharges * | 34,679 | 39,542 | | | 14%
< 1 year, total discharges | 4,426 | 5,125 | 100.0% | 100.0% | 16
Liveborn (newborn infant) | 3,776 | 4,539 | 85.3 | 88.6 | 20
Acute bronchitis | 108 | 92^‡^ | 2.4 | 1.8 | −15
Hemolytic jaundice and perinatal jaundice (infant jaundice following birth) | 33 | 43 | 0.7 | 0.8 | 31
Pneumonia | 55 | 34 | 1.3 | 0.7 | −39
Short gestation, low birth weight, and fetal growth retardation (premature birth and low birth weight) | 22 | 25^‡^ | 0.5 | 0.5 | 12
1–17 years, total discharges | 1,821 | 1,658 ‡ | 100.0 | 100.0 | −9
Asthma | 159 | 114 | 8.7 | 6.9 | −28
Pneumonia | 135 | 109 | 7.4 | 6.6 | −19
Mood disorders (depression and bipolar disorder) | 64 | 81^‡^ | 3.5 | 4.9 | 27
Appendicitis and other appendiceal conditions | 65 | 78 | 3.6 | 4.7 | 20
Fluid and electrolyte disorders (primarily dehydration or fluid overload) | 64 | 61^‡^ | 3.5 | 3.7 | −5
18–44 years, total discharges | 9,444 | 10,354 | 100.0 | 100.0 | 10
Trauma to external female genitals (vulva) and area between anus and vagina (perineum) due to childbirth | 676 | 833 | 7.2 | 8.0 | 23
Previous C-section | 270 | 558 | 2.9 | 5.4 | 107
Mood disorders (depression and bipolar disorder) | 335 | 386^‡^ | 3.5 | 3.7 | 15
Normal pregnancy and/or delivery | 511 | 299 | 5.4 | 2.9 | −41
Prolonged pregnancy | § | 264 | § | 2.6 | §
45–64 years, total discharges | 6,496 | 9,135 | 100.0 | 100.0 | 41
Coronary atherosclerosis (coronary artery disease) | 526 | 405 | 8.1 | 4.4 | −23
Non-specific chest pain | 242 | 381 | 3.7 | 4.2 | 57
Osteoarthritis (degenerative joint disease) | 105 | 323 | 1.6 | 3.5 | 206
Disorders of intervertebral discs and bones in spinal column (back problems) | 190 | 269 | 2.9 | 2.9 | 42
Pneumonia | 199 | 261 | 3.1 | 2.9 | 31
65–84 years, total discharges | 10,121 | 10,277 ‡ | 100.0 | 100.0 | 2
Congestive heart failure | 581 | 515 | 5.7 | 5.0 | −11
Coronary atherosclerosis (coronary artery disease) | 741 | 466 | 7.3 | 4.5 | −37
Pneumonia | 514 | 465 | 5.1 | 4.5 | −9
Osteoarthritis (degenerative joint disease) | 281 | 442 | 2.8 | 4.3 | 57
Cardiac dysrhythmias (irregular heart beat) | 333 | 379 | 3.3 | 3.7 | 14
85+ years, total discharges | 2,362 | 2,953 | 100.0 | 100.0 | 25
Congestive heart failure | 202 | 234 | 8.6 | 7.9 | 16
Pneumonia | 197 | 193^‡^ | 8.3 | 6.5 | −2
Septicemia (blood infection) | 76 | 126 | 3.2 | 4.3 | 64
Urinary tract infections | 75 | 118 | 3.2 | 4.0 | 58
Fracture of neck of femur (hip fracture) | 125 | 117^‡^ | 5.3 | 4.0 | −6

* Includes a small number of discharges (less than 41,000 or 0.1 percent) with missing age.

‡ 2007 discharges are [underlined: not] statistically different from 1997 discharges at p<0.05.

§ Consistent data are not available for this diagnosis due to coding changes that took place between 1997 and 2007.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2007.

The principal diagnoses for hospitalizations generally varied by age, although some conditions were frequent among all ages.

Infants, children and young adults:

- Pregnancy, childbirth, and newborns:
  - In 2007, most discharges for children under one year old (89 percent) were for liveborn infants, which increased 20 percent between 1997 and 2007.
  - Bronchitis accounted for another 1.8 percent and jaundice for another 0.8 percent of infant stays. Jaundice stays in infants increased 31 percent between 1997 and 2007.
  - Among 18–44 year olds, previous C-sections more than doubled between 1997 and 2007, while normal pregnancy and/or delivery fell 41 percent.
- Asthma among children 1–17 declined by 28 percent between 1997 and 2007.
- Appendicitis, also a common reason for hospital stays for children 1–17 in 2007, accounted for 5 percent of discharges in this age group, increasing 20 percent between 1997 and 2007.
- Depression and bipolar disorders (mood disorders) were the 3rd most common diagnoses for children 1–17 and adults 18–44.

Older adults:

- Cardiovascular conditions were the most common diagnoses for adults over 44 years old. However, specific diagnoses differed somewhat between age groups for older adults:
  - Coronary atherosclerosis (coronary artery disease) accounted for 4 percent of all discharges for adults 45–64; these stays declined by 23 percent between 1997 and 2007. This condition also ranked 2nd for 65–84 year olds (4.5 percent of stays in 2007), with stays declining 37 percent between 1997 and 2007.
  - Hospitalizations for non-specific chest pain in 45–64 year olds increased 57 percent between 1997 and 2007 and comprised 4 percent of stays in 2007.
  - Congestive heart failure (CHF) was the most common condition for adults 65–84 and 85 and older. In 2007, CHF accounted for 5 percent of all stays among adults 65–84 and 8 percent of all stays among adults 85 and older.
  - Irregular heart beat was the reason for 379,000 hospitalizations (3.7 percent) in 2007 among 65–84 year olds, an increase of 14 percent since 1997.
- Among adults 85 and older, hospitalizations for septicemia (up 64 percent) and urinary tract infections (up 58 percent) increased at more than twice the rate of all hospitalizations for this age group between 1997 and 2007.
- Musculoskeletal conditions:
  - Degenerative joint disease (osteoarthritis) more than tripled among adults 45–64 and increased 57 percent among adults 65–84.
  - Back problems increased 42 percent for 45–64 year olds between 1997 and 2007.
  - Hospital stays for hip fractures changed very little between 1997 and 2007 for patients 85 and older.

All patients:

- Pneumonia was a top five condition for all age groups except 18–44 year olds:
  - Hospital stays for pneumonia declined among children (a drop of 39 percent for children less than one and a 19-percent decline for children 1–17 years).
  - Pneumonia stays rose among adults 45–64 years (31 percent), but fell among adults 65–84 years (down 9 percent).
  - Stays remained relatively stable for adults 85 years and older.

## EXHIBIT 2.3 Most Frequent Principal Diagnoses by Gender

Number of Discharges, Percent Distribution, Rank and Growth of the Most Frequent Principal CCS Diagnoses for Inpatient Hospital Stays by Gender, 2007

PRINCIPAL CCS DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | | PERCENT OF GENDER-SPECIFIC DISCHARGES | | MALE PERCENT OF DIAGNOSIS-SPECIFIC | CUMULATIVE GROWTH 1997–2007
PRINCIPAL CCS DIAGNOSIS | MALES | FEMALES | MALES | FEMALES | DISCHARGES | MALES | FEMALES
All diagnoses^*^ | 16,231 | 23,203 | 100.0% | 100.0% | 41.0% | 14% | 13%
Chronic conditions^†^ | 6,914 | 7,501 | 42.6 | 32.3 | 47.9 | 5 | 4
Pregnancy and childbirth | | 5,022 | | 21.6 | 0.0 | | 16
Liveborn (newborn infant) | 2,322 | 2,212^‡^ | 14.3 | 9.5 | 51.2 | 20 | 20
Coronary atherosclerosis (coronary artery disease) | 601 | 362 | 3.7 | 1.6 | 62.4 | −28 | −37
Pneumonia | 562 | 608 | 3.5 | 2.6 | 48.0 | −6 | −4
Congestive heart failure | 500 | 524^‡^ | 3.1 | 2.3 | 48.8 | 11 | −3
Acute myocardial infarction (heart attack) | 373 | 252 | 2.3 | 1.1 | 59.6 | −16 | −13
Cardiac dysrhythmias (irregular heart beat) | 360 | 370^‡^ | 2.2 | 1.6 | 49.3 | 31 | 25
Non-specific chest pain | 352 | 435 | 2.2 | 1.9 | 44.7 | 43 | 50
Mood disorders (depression and bipolar disorder) | 330 | 442 | 2.0 | 1.9 | 42.7 | 32 | 13
Septicemia (blood infection) | 322 | 354 | 2.0 | 1.5 | 47.6 | 77 | 53
Skin and subcutaneous tissue infections | 320 | 282 | 2.0 | 1.2 | 53.1 | 90 | 75
Osteoarthritis (degenerative joint disease) | 314 | 498 | 1.9 | 2.1 | 38.7 | 96 | 94
Urinary tract infections | 152 | 383 | 0.9 | 1.7 | 28.4 | 30 | 32

* Excludes a small number of discharges (108,000 or 0.3 percent) with missing gender.

† Includes the number of discharges with a principal diagnosis that is considered to be a chronic condition.

‡ Female discharges are [underlined: not] statistically different from male discharges at p<0.05.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2007.

This exhibit shows the top 10 conditions for men and women in the hospital in addition to conditions related to childbirth and newborn infants. Most diagnoses are common to both males and females, if those related to childbirth are excluded. However, some diagnoses were more frequent in one gender, in part because of differences between males and females in health-seeking behaviors and attitudes.

- Females accounted for almost 6 out of every 10 hospital stays—23.2 million stays in 2007. About 22 percent of all female hospitalizations were related to pregnancy and childbirth.
- Males accounted for 16.2 million hospitalizations in 2007.
- Five heart-related diagnoses—coronary artery disease, congestive heart failure, heart attacks, cardiac dysrhythmias, and non-specific chest pain—were among the ten most common principal diagnoses for both male and female hospitalizations.
  - Males accounted for 62 percent of hospital stays for coronary artery disease and 60 percent of stays for heart attack. Hospitalizations for these conditions decreased for both males (coronary artery disease by 28 percent and heart attacks by 16 percent) and females (coronary artery disease by 37 percent and heart attacks by 13 percent) between 1997 and 2007.
  - The number of hospital stays for irregular heart beat (360,000 stays for males and 370,000 for females) and congestive heart failure (500,000 stays for males and 524,000 for females) were similar for males and females.
  - Women accounted for a greater share of hospitalizations for non-specific chest pain (55 percent of stays) than men (45 percent of stays).
- Women accounted for a greater number of hospital stays for mood disorders in 2007 than did men (442,000 female discharges versus 330,000 male discharges). The number of stays for mood disorders grew by 32 percent for men and by 13 percent for women between 1997 and 2007.
- Infections such as septicemia, skin and subcutaneous tissue infection, and urinary tract infection were common reasons for hospital stays among both men and women in 2007 and grew rapidly for both genders between 1997 and 2007.
  - Stays for septicemia rose 77 percent among men and 53 percent among women. In 2007, 2 percent of male hospital stays and 1.5 percent of female hospital stays were due to septicemia.
  - The number of stays for skin and subcutaneous tissue infections increased 90 percent for men and 75 percent for women. This condition accounted for 2 percent of male hospitalizations and 1.2 percent of female hospitalizations in 2007.
  - Growth was similar in stays for urinary tract infections for women (32 percent) and men (30 percent). In 2007, this condition was responsible for 1.7 percent of hospitalizations among women and 0.9 percent among men.
- Degenerative joint disease caused many more hospitalizations for females (498,000 discharges) than for males (314,000 discharges) in 2007. Over 61 percent of all discharges with this condition were for females. Hospital stays for degenerative joint disease grew at close to 100 percent for both males and females between 1997 and 2007.

## EXHIBIT 2.4 Most Frequent Comorbidities

Top Comorbidities and Percent of Discharges with Specific Comorbidity,* 2007

* Comorbidities are based on a classification of ICD-9-CM codes which is distinct from the Clinical Classification System.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2007.

Comorbidities^5^ are chronic disorders that are not the primary reason for hospitalization, but which may influence the course of hospitalization.

- Hypertension was a comorbidity in 35 percent of all hospital stays in 2007.
- Fluid and electrolyte disorders were comorbidities in 16 percent of hospital stays.
- Mental health conditions were among the top comorbidities in 2007, occurring singly or in combination with other mental health conditions. Depression occurred as a comorbid condition in 7 percent of stays in 2007 and alcohol abuse, drug abuse, and/or psychoses were each present in 3 percent of stays.
- Diabetes, both uncomplicated and with chronic complications, were comorbidities in 17 percent of all stays.
- Other notable comorbidities included chronic pulmonary disease, anemia, renal failure, hypothyroidism, congestive heart failure, and obesity.

1 Perrin EC, Newacheck P, Pless IB, Drotar D, Gortmaker SL, Leventhal J, Perrin JM, Stein RE, Walker DK, Weitzman M. Issues Involved in the Definition and Classification of Chronic Health Conditions. Pediatrics 91(4):787–793, 1993.

2 Paez KA, Zhao L, and Hwang W. Rising Out-Of-Pocket Spending For Chronic Conditions: A Ten-Year Trend. Health Affairs 28(1): 15–25, 2009.

3 For more information on the chronic condition tool, see http://www.hcup-us.ahrq.gov/toolssoftware/chronic/chronic.jsp.

4 Tu H, Cohen G. Financial and health burdens of chronic conditions grow. Track Report Apr;(24):1–6, 2009.

5 Comorbidities are different from secondary conditions, as secondary conditions may be directly related to the principal reason for hospitalization while comorbidities are not. For example, retinopathy may be a secondary condition in a hospital stay in which the principal diagnosis is diabetes. However, retinopathy would not be considered a comorbidity of diabetes, as it is a related condition.