# HCUP AND ITS DATA PARTNERS

Sponsored by the Agency for Healthcare Research and Quality (AHRQ), HCUP is a family of databases, software tools, and products developed through the collaboration of State data organizations, hospital associations, private data organizations, and the Federal government. The HCUP Partnership has grown from 8 states in 1988 to 40 states in 2009, and would not be possible without the current contributions from the following data collection Partners:

- Arizona Department of Health Services
- Arkansas Department of Health & Human Services
- California Office of Statewide Health Planning and Development
- Colorado Hospital Association
- Connecticut Hospital Association
- Florida Agency for Health Care Administration
- Georgia Hospital Association
- Hawaii Health Information Corporation
- Illinois Department of Public Health
- Indiana Hospital Association
- Iowa Hospital Association
- Kansas Hospital Association
- Kentucky Cabinet for Health and Family Services
- Maine Health Data Organization
- Maryland Health Services Cost Review Commission
- Massachusetts Division of Health Care Finance and Policy
- Michigan Health & Hospital Association
- Minnesota Hospital Association
- Missouri Hospital Industry Data Institute
- Nebraska Hospital Association
- Nevada Department of Health and Human Services
- New Hampshire Department of Health & Human Services
- New Jersey Department of Health and Senior Services
- New York State Department of Health
- North Carolina Department of Health and Human Services
- Ohio Hospital Association
- Oklahoma State Department of Health
- Oregon Association of Hospitals and Health Systems
- Rhode Island Department of Health
- South Carolina State Budget & Control Board
- South Dakota Association of Healthcare Organizations
- Tennessee Hospital Association
- Texas Department of State Health Services
- Utah Department of Health
- Vermont Association of Hospitals and Health Systems
- Virginia Health Information
- Washington State Department of Health
- West Virginia Health Care Authority
- Wisconsin Department of Health and Family Services
- Wyoming Hospital Association