# FOR MORE INFORMATION

## HCUP Background Information

For a detailed description of HCUP, information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Steiner C, Elixhauser A, Schnaier J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

2007 Introduction to the NIS. Healthcare Cost and Utilization Project (HCUP). June 2009. Agency for Healthcare Research and Quality, Rockville, MD (http://www.hcup-us.ahrq.gov/db/nation/nis/NIS_2007_INTRODUCTION.pdf).

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). Agency for Healthcare Research and Quality (http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf).

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006-05. Online. August 18, 2006. Agency for Healthcare Research and Quality (http://www.hcup-us.ahrq.gov/reports/2006_05_NISTrendsReport_1988-2004.pdf).

## HCUP Statistics and Website

Many of the statistics presented here were taken directly from HCUPnet, HCUP’s interactive query system. For additional HCUP statistics, visit HCUPnet at http://hcupnet.ahrq.gov.

## Technical Assistance

For Technical Assistance with HCUP Products:

E-mail: hcup@ahrq.gov

Phone: 1-866-290-HCUP