# ACKNOWLEDGMENTS

Thanks to Eva Witt and Nils Nordstrand at Thomson Reuters for programming support; Anne Pfuntner at Thomson Reuters for preparation of tables and text; Nancy Jordan, also at Thomson Reuters, for editorial assistance; and Kathy Hickey of Thomson Reuters for creating Web documents. This report draws from and updates previously published HCUP Fact Books and Statistical Briefs, which can be found at http://www.hcup-us.ahrq.gov/reports.jsp and http://www.hcup-us.ahrq.gov/reports/statbriefs.jsp.