# SOURCES AND METHODS

## Unit of Analysis

The unit of analysis is the hospital stay rather than the patient. All discharges have been weighted to produce national estimates.

## Coding Diagnoses and Procedures

Diagnoses and procedures associated with an inpatient hospitalization can be defined using several different medical condition classification systems. The following four systems are used within this report to identify specific diagnoses and procedures: International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM), Clinical Classifications Software (CCS), Diagnosis Related Groups (DRGs), and Major Diagnostic Categories (MDCs).

The most detailed system is the ICD-9-CM that contains over 13,600 detailed diagnoses and 3,700 detailed procedures. Each discharge record in the NIS is associated with one or more ICD-9-CM diagnosis code(s) and may contain one or more ICD-9-CM procedure code(s) if a procedure was performed during that hospitalization.

To make the number of ICD-9-CM diagnoses and procedures more manageable, AHRQ has designed the CCS tool that groups ICD-9-CM codes into about 280 diagnostic and 230 procedure categories. This software aggregates similar diagnoses or procedures into clinically meaningful categories. More information on CCS can be found online (http://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp). CCS codes are used extensively in this report to define groups of diagnoses and procedures for analysis. The CCS codes allow the reader to quickly and easily recognize patterns and trends in broad categories of hospital utilization.

In addition, diagnoses can also be grouped into DRGs. DRGs comprise a classification system that categorizes patients into groups, which are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedures), age, and other relevant criteria. Each hospital stay has one DRG assigned to it. The Centers for Medicare and Medicaid Services (CMS) uses this classification system as a basis for Medicare payments for inpatient hospital stays.

DRGs, in turn, can be summarized into MDCs, which are broad groups of DRGs such as Diseases and Disorders of the Nervous System or Diseases and Disorders of the Eye. Each hospital stay has one DRG and one MDC assigned to it.

## Exhibit Diagnoses and Procedures

Throughout this report, combinations of diagnostic and procedure codes are used to isolate specific conditions or procedures. These codes are defined below by exhibit number.

### SECTION 2 INPATIENT HOSPITAL STAYS BY DIAGNOSIS

#### EXHIBIT 2.1

Maternal CCS categories not listed on the exhibit table but included in total maternal discharges:

176 | Contraceptive and procreative management (birth control or helping with conception)
177 | Spontaneous abortion
178 | Induced abortion
179 | Postabortion complications (complications following abortion)
180 | Ectopic pregnancy (abdominal or tubal pregnancy)
181 | Other complications of pregnancy
182 | Hemorrhage during pregnancy, abruptio placenta, placenta previa (bleeding and placenta disorders during pregnancy)
186 | Diabetes or abnormal glucose tolerance complicating pregnancy, childbirth, or the puerperium (diabetes or high blood glucose during pregnancy)
187 | Malposition, malpresentation (breech birth and other disorders of baby’s position during birth)
188 | Obstructed labor or fetopelvic disproportion
194 | Forceps delivery
195 | Other maternal complications of birth, puerperium affecting management of mother (other maternal complications of birth and period after childbirth)

### SECTION 3 INPATIENT HOSPITAL STAYS BY PROCEDURE

#### EXHIBIT 3.3

Two steps were used to define maternal and infant procedures. First, all maternal and newborn stays were identified using the following codes:

Maternal stays were identified using Major Diagnostic Code 14: Pregnancy, childbirth and the puerperium.

Newborn stays were identified using the following CCS codes:

218 | Liveborn
219 | Short gestation, low birth weight, and fetal growth retardation
220 | Intrauterine hypoxia and birth asphyxia (lack of oxygen to baby in uterus or during birth)
221 | Respiratory distress syndrome
222 | Hemolytic jaundice and perinatal jaundice
223 | Birth trauma
224 | Other perinatal conditions (other conditions occurring around the time of birth)

Second, maternal and newborn stays were examined for the following CCS all-listed procedures that were typically associated with maternal and infant stays:

Maternal procedures:

133 | Episiotomy (surgical incision into the perineum and vagina to prevent traumatic tearing during delivery)
134 | Cesarean section
135 | Forceps, vacuum, and breech delivery
136 | Artificial rupture of membranes to assist delivery
137 | Other procedures to assist delivery
138 | Diagnostic amniocentesis (diagnostic sampling of the fluid in the amniotic sac)
139 | Fetal monitoring
140 | Repair of obstetric laceration
141 | Other therapeutic obstetrical procedures

Infant procedures:

115 | Circumcision
220 | Ophthalmologic and otologic diagnosis and treatment (vision and hearing diagnosis and treatment)
228 | Prophylactic vaccinations and inoculations

### SECTION 4 SPENDING FOR INPATIENT HOSPITAL STAYS

#### EXHIBIT 4.2

Top 6 most expensive circulatory system diagnoses:

100 | Acute myocardial infarction (heart attack)
101 | Coronary atherosclerosis (coronary artery disease)
102 | Non-specific chest pain
106 | Cardiac dysrhythmias (irregular heart beat)
108 | Congestive heart failure
109 | Acute cerebrovascular disease (stroke)

### SECTION 5 PRIORITY CONDITIONS

#### EXHIBIT 5.1

Childbirth DRG categories:

370 | Cesarean section with complications and comorbidities
371 | Cesarean section without complications and comorbidities
372 | Vaginal delivery with complicating diagnoses
373 | Vaginal delivery without complicating diagnoses
374 | Vaginal delivery with sterilization and/or dilation and curettage
375 | Vaginal delivery with operating room procedure except sterilization and/or dilation and curettage

Within DRG 370–371 and 372–375, all-listed diagnoses were also subsetted using the following CCS diagnosis categories to produce repeat C-section and Vaginal Birth After C-section (VBAC):

189 | Previous C-section

Childbirth complication CCS categories:

59 | Deficiency and other anemia
182 | Hemorrhage during pregnancy, abruptio placenta, placenta previa (bleeding and placenta disorders during pregnancy)
183 | Hypertension complicating pregnancy, childbirth, and the puerperium (high blood pressure during pregnancy)
184 | Early or threatened labor
186 | Diabetes or abnormal glucose tolerance complicating pregnancy, childbirth, or the puerperium (diabetes or high blood glucose during pregnancy)
187 | Malposition, malpresentation (breech birth and other disorders of baby’s position during birth)
188 | Obstructed labor or fetopelvic disproportion
189 | Previous C-section
191 | Polyhydramnios and other problems of amniotic cavity (excess amniotic fluid and other problems of amniotic cavity)
192 | Umbilical cord complication

Infant delivery type ICD-9-CM codes:

V30–V39 | Liveborn infants
.00 | delivered without mention of cesarean delivery (vaginal delivery)
.01 | delivered by cesarean delivery

Infant complication ICD-9-CM codes (selected ICD-9-CM codes were grouped together for graphic display):

Preterm birth:

765.0 | Extreme immaturity
765.1 | Other preterm infant

Meconium aspiration:

770.1 | Fetal and newborn aspiration

Post-birth respiratory problems:

770.8 | Other respiratory problems after birth

Neonatal jaundice:

774.2 | Neonatal jaundice associated with preterm delivery
774.6 | Unspecified fetal and neonatal jaundice

Other conditions listed separately:

761.1 | Premature rupture of membrane affecting newborn
766.0 | Exceptionally large baby
766.1 | Heavy-for-dates infant
768.3 | Fetal distress during labor
769 | Respiratory distress syndrome
770.6 | Transitory tachypnea
772.6 | Cutaneous hemorrhage
773.1 | Hemolytic disease due to ABO isoimmunization
775.0 | “Infant of a diabetic mother” syndrome
775.6 | Neonatal hypoglycemia
779.3 | Feeding problems

#### EXHIBIT 5.2

Depression ICD-9-CM codes:

293.83 | Mood disorder in conditions classified elsewhere- Transient organic psychotic condition, depressive type
296.2 | Major depressive disorder, single episode
296.3 | Major depressive disorder, recurrent episode
300.4 | Dysthymic disorder
311 | Depressive disorder, not elsewhere classified

Other Mental Health and Substance Abuse Secondary Conditions were identified in the following CCS-MHSA categories that were created using the CCS-MHSA tool:

650 | Adjustment disorders
651 | Anxiety disorders
652 | Attention-deficit, conduct, and disruptive behavior disorders
653 | Delirium, dementia, and amnestic and other cognitive disorders
654 | Developmental disorders
655 | Disorders usually diagnosed in infancy, childhood, or adolescence
656 | Impulse control disorders, not elsewhere classified
657 | Mood disorders
658 | Personality disorders
659 | Schizophrenia and other psychotic disorders
660 | Alcohol-related disorders
661 | Substance-related disorders

#### EXHIBIT 5.3

Cancer CCS categories:

11 | Cancer of head and neck
12 | Cancer of esophagus
13 | Cancer of stomach
14 | Cancer of the colon
15 | Cancer of rectum and anus
16 | Cancer of liver and intrahepatic bile duct
17 | Cancer of pancreas
18 | Cancer of GI organs and peritoneum
19 | Cancer of bronchus, lung
20 | Cancer, other respiratory and intrathoracic
21 | Cancer of bone and connective tissue
22 | Melanomas of skin
23 | Other non-epithelial cancer of skin
24 | Cancer of breast
25 | Cancer of uterus
26 | Cancer of cervix
27 | Cancer of ovary
28 | Cancer of other female genital organs
29 | Cancer of prostate
30 | Cancer of testis
31 | Cancer of other male genital organs
32 | Cancer of bladder
33 | Cancer of kidney and renal pelvis
34 | Cancer of other urinary organs
35 | Cancer of brain and nervous system
36 | Cancer of thyroid
37 | Hodgkin’s disease
38 | Non-Hodgkin’s lymphoma
39 | Leukemias
40 | Multiple myeloma
41 | Cancer, other primary
43 | Malignant neoplasm without specification of site
44 | Neoplasms of unspecified nature or uncertain behavior
** | Multiple cancer sites
** | No specific sites listed

** CCS Diagnosis Code 42 ‘Secondary malignancies’ and 45 ‘Maintenance chemotherapy, radiotherapy’ were reclassified and discharges were assigned to a specific cancer category listed as a secondary condition. If no secondary cancer diagnosis was listed, then discharges for CCS diagnosis codes 42 and 45 were counted as ‘No specific sites listed.’ If multiple secondary CCS diagnoses were listed, then CCS diagnosis codes 42 and 45 discharges were counted as ‘Multiple cancer sites.’

#### EXHIBIT 5.4

Asthma CCS category:

128 | Asthma

#### EXHIBIT 5.5

Arthritis CCS categories:

202 | Rheumatoid arthritis and related disease
203 | Osteoarthritis