# PRIORITY CONDITIONS

## EXHIBIT 5.1 Childbirth

Vaginal and C-Section Deliveries as a Share of All Deliveries, 1993 and 2006

Maternal Stays for C-Section and Vaginal Deliveries,† 1993–2006

† Based on DRGs.

In 2006, there were 4.3 million maternal stays that resulted in a delivery.

- Vaginal births accounted for the majority of these stays (68 percent), but this was a significant decline since 1993 when vaginal births accounted for 78 percent of all deliveries.
- Both first time C-sections and repeat C-sections grew rapidly—by 55 percent and 98 percent, respectively—between 1998 and 2006.
- During the same period, the number of vaginal births after C-section (VBAC) decreased by 60 percent, from 156,000 to 62,000 cases.

Maternal Stays for C-Section and Vaginal Deliveries, 1993–2006

| TOTAL | ALL DELIVERIES IN THOUSANDS
| TOTAL | VAGINAL | | C-SECTION
| TOTAL | TOTAL | AFTER C-SECTION | TOTAL | FIRST-TIME
1993 | 3,774 | 2,958 | 138 | 817 | 518
1994 | 3,784 | 2,982 | 152 | 802 | 508
1995 | 3,768 | 2,977 | 157 | 791 | 507
1996 | 3,744 | 2,964 | 162 | 780 | 498
1997 | 3,809 | 3,010 | 160 | 799 | 506
1998 | 3,750 | 2,963 | 156 | 787 | 497
1999 | 3,840 | 2,993 | 145 | 848 | 532
2000 | 4,058 | 3,127 | 138 | 931 | 577
2001 | 3,980 | 2,986 | 112 | 995 | 600
2002 | 4,128 | 3,025 | 94 | 1,103 | 659
2003 | 4,052 | 2,882 | 76 | 1,170 | 695
2004 | 4,217 | 2,946 | 70 | 1,270 | 748
2005 | 4,192 | 2,889 | 62 | 1,303 | 756
2006 | 4,259 | 2,914 | 62 | 1,345 | 772

Overall, maternal complications are more commonly listed among women undergoing C-sections than among women who deliver vaginally. Some of these complications provide the rationale for performing C-sections.

- In 2006, the most common all-listed diagnosis for women who had a C-section procedure was a previous C-section. As more C-sections were performed and repeat C-sections were further encouraged, the share of all C-sections with this condition rose. At the same time, previous C-section complications fell as a share of vaginal deliveries.
- Complications due to hypertension, diabetes, and anemia increased among both C-section and vaginal deliveries between 1993 and 2006, but were present in a higher proportion of C-section than vaginal deliveries.
  - Among C-section deliveries, the share complicated by hypertension rose from 10 percent to 13 percent, the share complicated by diabetes rose from 6 percent to 9 percent, and the share complicated by anemia rose from 3 percent to 8 percent.
- Umbilical cord complication was the only major complicating condition that occurred in a greater share of vaginal deliveries (24 percent) than of C-section deliveries (16 percent).
- The largest decline in delivery complications was for C-section deliveries involving fetopelvic disproportion. This condition complicated 23 percent (190,000) of C-section deliveries in 1993, but only 10 percent (136,000) of these deliveries in 2006.
  - Other declines in complications for C-section deliveries included malposition/malpresentation (present in 23 percent of these deliveries in 1993 and 19 percent in 2006) and problems of the amniotic cavity (affecting 16 percent of C-section deliveries in 1993 and 13 percent in 2006).
  - For vaginal deliveries, previous C-section complications affected a smaller share of deliveries (5 percent in 1993 but only 2 percent in 2006).

Percent of Maternal Stays with Complications† by Delivery Type, 1993 and 2006

† Based on all-listed diagnosis.

- In 2006, 1.4 million infants were delivered by C-section and 2.9 million infants were delivered vaginally.
- The most common complication experienced by newborns was jaundice—affecting 26 percent of C-section delivered infants, but only 16 percent of vaginally delivered infants.
- Thirteen percent of infants delivered by C-section (183,400) were premature, compared with 6 percent of vaginally delivered infants (168,600).
- Post-birth respiratory problems not elsewhere classified, transitory tachypnea and respiratory distress syndrome were each diagnosed in 4 to 7 percent of infants delivered by C-section, but in just 1 to 3 percent of infants born by vaginal delivery.
- While feeding problems affected 4 percent of C-section infants, they affected only 2 percent of vaginally delivered infants.
- Two percent of infants born by C-section experienced neonatal hypoglycemia and “infant of a diabetic mother” syndrome, but only one percent of vaginally born infants experienced these complications.
- Cutaneous hemorrhages affected a greater share of vaginally born infants (1 percent) than of C-section delivered infants (0.5 percent).
- Fetal and newborn aspiration affected a greater share of C-section delivered infants (0.6 percent) than of vaginally delivered infants (0.4 percent).

Number of Infant Complications† by Delivery Type, 2006

† Based on all-listed diagnosis.

* Not elsewhere classified.

Between 1993 and 2006, the number of infant births grew from 3.8 million to 4.3 million. The number of vaginally delivered infants did not change significantly in this period. However, the number of infants born by C-section increased by 0.6 million, or 69 percent, at an annual rate of 4 percent.

- Several complications declined over time among infants born by C-section: fetal distress during labor (−12 percent annually), premature rupture of membrane affecting newborn (−5 percent annually), fetal and newborn aspiration (−2 percent annually), and exceptionally large baby (−2 percent annually).
- Among infants delivered by C-section, transitory tachypnea, heavy-for-dates infant, and respiratory distress syndrome diagnoses grew at about the same rate as C-section deliveries.
- Several complications grew more quickly than the 4 percent average annual growth in the number of C-section births, including post-birth respiratory problems not elsewhere classified (6 percent annually), “infant of a diabetic mother” syndrome (7 percent annually), jaundice (7 percent annually), and feeding problems not elsewhere classified (11 percent annually).
- Several complications grew among vaginally-delivered infants. These included feeding problems and jaundice, two diagnoses which also grew among C-section delivered infants.
- Diagnoses of fetal distress during labor, premature rupture of membrane affecting newborn, and fetal and newborn aspiration declined among vaginally delivered infants, as they did among C-section infants, between 1993 and 2006. Average annual decline for these diagnoses ranged from 17 percent (fetal distress during labor) to 3 percent (meconium aspiration).

Average Annual Growth of Infant Complications† by Delivery Type, 1993–2006

† Based on all-listed diagnosis.

* Not elsewhere classified.

## EXHIBIT 5.2 Depression

Distribution of Discharges with a Principal Diagnosis of Depression† and All Discharges by Age Group,* 2006

† Based on principal ICD-9-CM diagnosis codes.

* Excludes a small number of discharges (less than 38,000 or 0.1 percent) with missing age.

Depression, including major depressive disorder and dysthymic disorder (chronic, mild depression), is a leading cause of disability in the US, affecting about 18 million adults.^1^

1 Kessler RC, Chiu WT, Demler O, Walters EE. Prevalence, Severity, and Comorbidity of Twelve-month DSM-IV Disorders in the National Comorbidity Survey Replication (NCS-R). 2005 Archives of General Psychiatry 62(6):617-27, 2005.

- In 2006, there were 423,000 hospital stays with a principal diagnosis of depression.
- The average length of stay (ALOS) for depression was 6.4 days, compared to an ALOS of 4.6 days for all hospitalizations.
- About 45 percent of these discharges were admitted through the emergency department, a proportion similar to that of all discharges (44 percent).
- Younger patients comprised a larger share of hospital stays for depression (57 percent) than for overall hospitalizations (35 percent) in 2006.

Patients hospitalized for depression are often diagnosed with comorbid (or secondary) psychiatric and physical conditions.^2^

2 Katon W. Clinical and Health Services Relationships between Major Depression, Depressive Symptoms, and General Medical Illness. Biological Psychiatry 54(3):216–226, 2003.

- Secondary mental health and substance abuse conditions were prevalent comorbidities for depression among both younger and older patients.
  - The most common secondary diagnosis among individuals ages 1–44 hospitalized for depression was substance abuse, which was diagnosed in 36 percent of depression discharges in this age group. This was one and a half times the rate seen in older patients in the hospital for depression.
  - Personality disorders were recorded more often as secondary conditions in depression discharges among younger patients (19 percent of their depression stays) than among patients 45 and older (13 percent of their depression stays).
  - Alcohol related disorders, anxiety disorders, and suicide and intentional self-injury appeared as comorbid conditions in similar shares of depression discharges for both younger and older age groups. Altogether, one out of four discharges for depression was also diagnosed with an alcohol related disorder. More than one out of five patients hospitalized for depression also had an anxiety disorder or had a diagnosis of suicide attempt and intentional self-injury.

Percent of Depression Stays with Secondary Chronic Conditions or Secondary Mental Health and Substance Abuse Diagnoses by Age, 2006

Depression may be caused or exacerbated by multiple medical conditions. Because older adults often have multiple chronic conditions, they are particularly vulnerable to depression. Other chronic conditions add to the complexity of a depression diagnosis and can be responsible for under-diagnosis of this condition.^3^

3 Hitchcock PN, Williams JW, Unützer J, et al. Depression and Comorbid Illness in Elderly Primary Care Patients: Impact on Multiple Domains of Health Status and Well-being. Annals of Family Medicine 2:555–562, 2004.

- Overall, chronic physical (rather than psychiatric) conditions were more common among older age patients hospitalized for depression.
  - Secondary diagnoses of disorders of hypertension, lipid metabolism, esophageal disorders, diabetes, and thyroid disorders were more likely in the older rather than the younger age groups hospitalized for depression.

Discharge Prevalence for Depression by Median Income of Patient Zip Code, 2006

Nationwide, there were 142 discharges per 100,000 population for depression in 2006. The rate at which patients were hospitalized with a principal diagnosis of depression in 2006 varied by income^4^ and by region.

4 Daniel J, Honey W, Landen M, Marshall-Williams S, Chapman D, Lando J. Mental Health in the United States: Health Risk Behaviors and Conditions Among Persons with Depression—New Mexico, 2003. Center for Disease Control Morbidity and Mortality Weekly Report 54(39):989–91, October 7, 2005; Beard JR, Tracy M, Vlahov D, Galea S. Trajectory and Socioeconomic Predictors of Depression in a Prospective Study of Residents of New York City. Annals of Epidemiology 18(3):235–43, March 2008.

- Patients living in the lowest income communities tended to have higher rates of hospitalization for depression than persons in the highest income communities.^4^
  - The rates of hospitalization for depression in communities with median incomes of $1–37,999 and $38,000–46,999 (161 and 146 per 100,000 persons, respectively) were 43 percent and 30 percent higher than the rates of depression hospitalization in the highest income communities.

Discharge Prevalence for Depression by Region, 2006

- The West had the lowest rate of hospitalization for depression of any region—62 stays per 100,000 individuals.
- Compared to the West, discharges for depression occurred at twice the rate in the South, and around three times the rate in the Northeast and Midwest.

## EXHIBIT 5.3 Cancer

- There were 1.45 million hospitalizations for cancer in 2006, a decline of almost ten percent from the 1.60 million discharges for cancer in 1997.
- During this period, the number of hospital stays for cancer changed considerably for certain diagnoses.
  - The number of breast cancer hospitalizations changed the most, declining by 56,000 discharges, or 32 percent during this period. This decline is likely due to an increase in breast cancer procedures performed in outpatient settings.
  - Hospitalizations for lung cancer—the cancer diagnosis which caused the greatest number of deaths in 2006^5^ as well as the greatest number of hospital stays—also decreased substantially, with 21,000, or 10 percent, fewer stays for lung cancer in 2006 than 1997.
    5 Cancer Facts and Figures, 2006. Online. 2006. American Cancer Society. http://www.cancer.org/downloads/STT/CAFF2006PWSecured.pdf
  - Hospital stays for Hodgkin’s disease, kidney cancer and liver cancer all increased by over 25 percent between 1997 and 2006.
  - There were substantive decreases in the number of hospital stays for head and neck cancer (−17 percent), prostate cancer (−17 percent), bladder cancer (−20 percent), ovarian cancer (−30 percent), and cervical cancer (−39 percent).

Cancer Conditions with the Greatest Change in Number of Discharges Between 1997 and 2006

Discharge Prevalence for Cancer by Region, 2006

- The prevalence of hospital stays for cancer was lowest in the West (422 discharges per 100,000 population) and highest in the Midwest (543 discharges per 100,000 population).
- Overall, lung cancer was the most common reason for a cancer-related hospital stay, with 200,000 discharges in 2006.
  - Among men, lung cancer was the top reason for cancer-related hospitalizations, followed by prostate cancer.
  - Among women hospitalization related to breast cancer was more likely while cancer stays for lung cancer ranked second.
- For both men and women, colon cancer was the third most frequent cause of a cancer-related hospital stay.

Most Frequent Hospitalizations with a Principal Diagnosis of Cancer by Gender, 2006

## EXHIBIT 5.4 Asthma

Rate of Asthma Hospitalizations by Patient Gender and Age, 2006

- There were 420,900 hospitalizations for asthma in 2006. Six out of every ten hospital stays were for women (256,100 stays) and almost one-third (133,700 stays) were for children under the age of 18.
- The rate of hospital stays for asthma was generally higher for females than males, except among children ages 0–17 years. Among males younger than 18 years of age, the rate of hospital stays for asthma was 1.6 times the rate among females of the same age.

Distribution of Discharges with a Principal Diagnosis of Asthma by Expected Primary Payer, 1997 and 2006

* Includes other payers such as Workers’ Compensation, TRICARE, CHAMPUS, Title V, and other government programs.

** Includes discharges classified as self-pay or no charge.

- In 2006, discharges with a principal diagnosis of asthma were more likely than all discharges to be covered by Medicaid or to be uninsured.
- The share of asthma discharges covered by Medicare increased by 12 percentage points between 1997 and 2006; the share covered by private insurance decreased by 11 percentage points in the same period.

Rates of Asthma Hospitalization by Median Income of Patient Zip Code and Region, 2006

- The prevalence of hospital stays for a principal diagnosis of asthma was greater in the lowest income communities than it was in the highest income communities in all regions of the country.
  - This higher prevalence of asthma-related stays in low-income communities was particularly distinct in the Northeast and Midwest regions where there were three times more discharges per 100,000 population in the lowest income communities compared with the highest income communities.

## EXHIBIT 5.5 Arthritis

Hospitalizations with a Principal Diagnosis of Arthritis, 1993–2006

- The number of hospitalizations with a principal diagnosis of arthritis more than doubled between 1993 and 2006—from 362,600 to 754,000.
- All of the increase in arthritis-related stays was due to osteoarthritis, which increased by 121 percent between 1993 (322,200 discharges) and 2006 (735,100 discharges). The number of stays for rheumatoid arthritis actually declined by 38 percent from 30,400 discharges in 1993 to 18,900 discharges in 2006.

Number of Arthritis Stays by Type of Arthritis, Gender, and Age, 2006

- The number of hospitalizations for all types of arthritis combined generally increased with age. In 2006, 93 percent of all arthritis stays were for persons ages 45–84.
- Hospitalizations for arthritis occurred in greater numbers for females than for males. Hospital stays for women accounted for 75 percent of stays with a principal diagnosis of rheumatoid arthritis and 62 percent of stays for osteoarthritis.

Percent of Specific Joint Procedures with Arthritis as a Principal Diagnosis, 2006

- Arthritis discharges accounted for a substantial proportion of the hospital stays for joint procedures in 2006.
  - Of the 547,400 stays in which an arthroplasty of the knee was performed in 2006, nine out of every ten had a principal diagnosis of arthritis.
  - In 2006, there were 369,400 stays for a hip replacement and 55,600 stays for arthroplasty other than for the hip or knee. Discharges with a principal diagnosis of arthritis accounted for about half of all stays for total and partial hip replacement (52 percent) and non-knee and non-hip arthroplasty (50 percent).