# INPATIENT HOSPITAL STAYS BY PROCEDURE

## EXHIBIT 3.1 Most Frequent All-listed Procedures

Number, Percent Distribution, Rank, and Growth of Discharges for the Most Frequent All-listed Inpatient Hospital Procedures, 1997, 2005, and 2006

ALL-LISTED CCS PROCEDURES | NUMBER OF STAYS WITH THE PROCEDURE IN THOUSANDS | | | PERCENT OF DISCHARGES WITH THE PROCEDURE | | | RANK | | | GROWTH
ALL-LISTED CCS PROCEDURES | 1997 | 2005 | 2006 | 1997 | 2005 | 2006 | 1997 | 2005 | 2006 | 1997–2006
All discharges (with and without procedures) | 34,679 | 39,164 | 39,450 | | | | | | | 14%
All discharges with any procedure | 21,257 | 24,145 | 24,445 | 100% | 100% | 100% | | | | 15
Percent of all discharges with a procedure | 61% | 62% | 62%
Blood transfusion | 1,097 | 2,359 | 2,382 | 5 | 10 | 10 | 5 | 1 | 1 | 117
Diagnostic cardiac catheterization, coronary arteriography (diagnostic procedure to explore the functioning of the heart) | 1,461 | 1,589 | 1,671 | 7 | 7 | 7 | 1 | 2 | 2 | 14
Repair of obstetric laceration | 1,137 | 1,334 | 1,373 | 5 | 6 | 6 | 3 | 3 | 3 | 21
Cesarean section (C-section) | 800 | 1,304 | 1,346 | 4 | 5 | 6 | 9 | 4 | 4 | 68
Respiratory intubation and mechanical ventilation | 919 | 1,223 | 1,294 | 4 | 5 | 5 | 7 | 7 | 5 | 41
Circumcision | 1,164 | 1,237 | 1,224 | 5 | 5 | 5 | 2 | 5 | 6 | 5
Upper gastrointestinal endoscopy (procedure to view and biopsy the esophagus, stomach, and first portion of intestine through a lighted tube) | 1,105 | 1,224 | 1,213 | 5 | 5 | 5 | 4 | 6 | 7 | 10
Artificial rupture of membranes to assist delivery | 747 | 885 | 1,007 | 4 | 4 | 4 | 10 | 10 | 8 | 35
Fetal monitoring | 1,002 | 911 | 958 | 5 | 4 | 4 | 6 | 9 | 9 | −4
Prophylactic vaccinations and inoculations | 567 | 954 | 945 | 3 | 4 | 4 | 14 | 8 | 10 | 67
Episiotomy (surgical incision into the perineum and vagina to prevent traumatic tearing during delivery) | 866 | 444 | 393 | 4 | 2 | 2 | 8 | 22 | 24 | −55

During six out of ten hospital stays in 2006, at least one procedure was performed, and this proportion has changed little since 1997. The number of discharges with procedures increased from 21.3 million in 1997 to 24.4 million in 2006, a 15 percent increase.

- The top 10 all-listed procedures performed in 2006 accounted for 55 percent of all procedures performed in that year.
  - Blood transfusions occurred in one out of every ten hospital stays that included a procedure and was the most frequently performed procedure in both 2005 and 2006.
- With only two exceptions, little change occurred in the list of the top 10 procedures performed in U.S. hospitals since 1997.
  - Vaccinations were added to the list of top 10 procedures, rising in rank from 14th in 1997 to 10th in 2006. These vaccinations were overwhelmingly hepatitis B immunizations for newborns.
  - Episiotomy fell from the list of top 10 procedures, dropping in rank from 8th in 1997 to 24th in 2006.
- C-section was the most frequent major therapeutic (as opposed to diagnostic) procedure—performed on 1.3 million women in 2006.
- Seven of the top 10 procedures in 1997, 2005 and/or 2006 were associated with giving birth and newborns.
  - Of the top-ranked maternal and newborn procedures, C-sections and vaccinations increased at the fastest pace—68 and 67 percent respectively.
  - Between 1997 and 2006, the number of hospital stays with repair of current obstetric laceration and artificial rupture of membrane to assist delivery increased by 21 and 35 percent, respectively.
  - The number of hospital stays in which episiotomies were performed declined at a faster rate than any of the most frequent procedures—by 55 percent from 1997 to 2006.
  - There has been little change in the number of discharges for circumcision or fetal monitoring since 1997.

Number of Stays with the Most Frequent All-listed Maternal and Newborn Procedures, 1997–2006

- The remaining most frequent procedures were not related to giving birth or to newborns.
  - Discharges with blood transfusions have more than doubled since 1997. There were 1.1 million of stays with this procedure in 1997 and 2.4 million in 2006, an increase of 117 percent, making this the most frequent as well as the fastest growing of the most common procedures performed during a hospital stay.
  - From a peak in 2001, discharges with diagnostic catheterization and coronary arteriography have remained relatively stable through 2006 while discharges with upper gastrointestinal (GI) endoscopy have fallen by 9 percent.
  - Discharges with respiratory intubation and mechanical ventilation have risen steadily, from 0.9 million in 1997 to 1.3 million in 2006—a 41 percent increase.

Number of Stays with the Most Frequent All-listed Procedures (Excluding Maternal and Newborn Stays), 1997–2006

## EXHIBIT 3.2 Most Frequent All-listed Procedures by Age

Number of Discharges, Percent Distribution, and Growth for the Most Frequent All-listed Inpatient Hospital Procedures by Age Group, 1997, 2005, and 2006

AGE GROUP AND ALL-LISTED CCS PROCEDURES | NUMBER OF DISCHARGES IN THOUSANDS | | | PERCENT OF AGE-SPECIFIC TOTAL DISCHARGES | | | GROWTH
AGE GROUP AND ALL-LISTED CCS PROCEDURES | 1997 | 2005 | 2006 | 1997 | 2005 | 2006 | 1997–2006
All ages, total discharges^†^ | 34,679 | 39,164 | 39,450 | | | | 14%
< 1 year, total discharges | 4,426 | 4,978 | 4,908 | 100.0% | 100.0% | 100.0% | 11
Circumcision | 1,159 | 1,232 | 1,220 | 26.2 | 24.7 | 24.9 | 5
Prophylactic vaccinations and inoculations | 549 | 865 | 845 | 12.4 | 17.4 | 17.2 | 54
Ophthalmologic and otologic diagnosis and treatment (vision and hearing diagnosis and treatment) | * | 471 | 406 | * | 9.5 | 8.3 | *
Respiratory intubation and mechanical ventilation | 163 | 196 | 197 | 3.7 | 3.9 | 4.0 | 21
Enteral and parenteral nutrition | 39 | 101 | 106 | 0.9 | 2.0 | 2.2 | 173
1–17 years, total discharges | 1,821 | 2,059 | 1,711 | 100.0 | 100.0 | 100.0 | −6
Appendectomy (removal of appendix) | 74 | 95 | 84 | 4.1 | 4.6 | 4.9 | 13
Repair of obstetric laceration | 58 | 54 | 56 | 3.2 | 2.6 | 3.3 | −4
Blood transfusion | 26 | 59 | 45 | 1.4 | 2.9 | 2.6 | 72
Cancer chemotherapy | 43 | 64 | 40 | 2.4 | 3.1 | 2.3 | −7
Artificial rupture of membranes to assist delivery | 40 | 34 | 39 | 2.2 | 1.6 | 2.3 | −4
18–44 years, total discharges | 9,444 | 10,041 | 10,212 | 100.0 | 100.0 | 100.0 | 8
Repair of obstetric laceration | 1,079 | 1,278 | 1,316 | 11.4 | 12.7 | 12.9 | 22
Cesarean section (C-section) | 773 | 1,270 | 1,312 | 8.2 | 12.6 | 12.8 | 70
Artificial rupture of membranes to assist delivery | 706 | 850 | 968 | 7.5 | 8.5 | 9.5 | 37
Fetal monitoring | 952 | 876 | 919 | 10.1 | 8.7 | 9.0 | −3
Episiotomy (surgical incision into the perineum and vagina to prevent traumatic tearing during delivery) | 813 | 418 | 370 | 8.6 | 4.2 | 3.6 | −55
45–64 years, total discharges | 6,496 | 8,660 | 9,100 | 100.0% | 100.0% | 100.0% | 40%
Diagnostic cardiac catheterization, coronary arteriography (diagnostic procedure to explore the functioning of the heart) | 578 | 674 | 723 | 8.9 | 7.8 | 7.9 | 25
Blood transfusion | 247 | 601 | 623 | 3.8 | 6.9 | 6.8 | 152
PTCA (percutaneous transluminal coronary angioplasty, procedure involving use of a balloon-tipped catheter to enlarge a narrowed artery) | 247 | 349 | 398 | 3.8 | 4.0 | 4.4 | 61
Upper gastrointestinal endoscopy (procedure to view and biopsy the esophagus, stomach and first portion of intestine through a lighted tube) | 275 | 356 | 368 | 4.2 | 4.1 | 4.0 | 34
Respiratory intubation and mechanical ventilation | 186 | 310 | 348 | 2.9 | 3.6 | 3.8 | 87
65–84 years, total discharges | 10,121 | 10,449 | 10,512 | 100.0 | 100.0 | 100.0 | 4
Blood transfusion | 514 | 1,059 | 1,072 | 5.1 | 10.1 | 10.2 | 109
Diagnostic cardiac catheterization, coronary arteriography (diagnostic procedure to explore the functioning of the heart) | 738 | 727 | 755 | 7.3 | 7.0 | 7.2 | 2
Upper gastrointestinal endoscopy (procedure to view and biopsy the esophagus, stomach and first portion of intestine through a lighted tube) | 530 | 524 | 509 | 5.2 | 5.0 | 4.8 | −4
Respiratory intubation and mechanical ventilation | 366 | 430 | 454 | 3.6 | 4.1 | 4.3 | 24
PTCA (percutaneous transluminal coronary angioplasty, procedure involving use of a balloon-tipped catheter to enlarge a narrowed artery) | 286 | 376 | 426 | 2.8 | 3.6 | 4.1 | 49
85+ years, total discharges | 2,362 | 2,926 | 2,970 | 100.0 | 100.0 | 100.0 | 26
Blood transfusion | 138 | 318 | 324 | 5.8 | 10.9 | 10.9 | 135
Upper gastrointestinal endoscopy (procedure to view and biopsy the esophagus, stomach and first portion of intestine through a lighted tube) | 122 | 142 | 139 | 5.2 | 4.9 | 4.7 | 14
Respiratory intubation and mechanical ventilation | 65 | 94 | 98 | 2.8 | 3.2 | 3.3 | 50
Treatment, fracture or dislocation of hip and femur | 87 | 87 | 84 | 3.7 | 3.0 | 2.8 | −3
Colonoscopy and biopsy | 71 | 77 | 74 | 3.0 | 2.6 | 2.5 | 4

* Statistics based on estimates with a relative standard error (standard error/weighted estimate) greater than 0.30 or with standard error = 0 in the nationwide statistics are not reliable.

† Includes a small number of discharges (less than 38,000 or 0.1 percent) with missing age.

The most frequent procedures tended to vary by age group.

- The most common procedures performed on infants included routine procedures, such as circumcision (performed on 24.9 percent of all infants, or 47.8 percent of all male infants) and vaccinations (performed on 17.2 percent of all infants).
  - In 2006, over 1.2 million circumcisions were performed in the hospital.
  - Procedures on infants also included those done for complex conditions affecting severely ill babies, such as respiratory intubation (performed on 197,000 infants in 2006) and enteral/parenteral nutrition, or tube feeding (performed on 106,000 infants in 2006). The use of tube feeding in infants increased 173 percent, nearly tripling over the past 10 years.
- Appendectomy was the most common procedure for children ages 1–17. Other top procedures included repair of obstetric laceration in teen deliveries, blood transfusion, cancer chemotherapy, and artificial rupture of membranes to assist in teen delivery.
- Pregnancy- and childbirth-related procedures accounted for all five of the most common procedures for individuals ages 18–44.
  - Repair of obstetric laceration and C-sections were the most frequently performed procedures. Each of these procedures occurred in 1.3 million discharges. C-sections increased by 70 percent from 1997 to 2006, faster than any of the other top five procedures for this age group.
  - Episiotomy, a surgical incision to prevent traumatic tearing during vaginal delivery, was the fifth most frequently occurring procedure in this age group. However, the number of these procedures decreased by 55 percent between 1997 and 2006.
  - Other common procedures included artificial rupture of membranes to assist delivery and fetal monitoring.
- In 2006, the five most frequently performed procedures were the same for individuals ages 45–64 and ages 65–84, although their rank order differed.
  - Diagnostic procedure to explore the functioning of the heart was the leading procedure for 45–64 year olds and the second most frequently performed procedure for 65–84 year olds.
  - PTCA (percutaneous transluminal coronary angioplasty—a procedure involving the use of a balloon-tipped catheter to enlarge a narrowed artery) was performed in 4 percent of the hospital stays in each of these age groups.
  - Other common procedures for these age groups were upper GI endoscopy and respiratory intubation/mechanical ventilation.
- For patients ages 85 and above, treatment of a fracture or dislocation of the hip and femur, and colonoscopy and biopsy were among the top 5 procedures performed during a hospital stay.
- Blood transfusion was a top five procedure in all age groups except infants less than 1 year and individuals ages 18–44. It was the third most common procedure for 1–17 year olds; second for adults ages 45–64, and first for adults 65–84 and 85 and older.
  - Blood transfusion was one of the fastest growing procedures from 1997 to 2006: 72 percent increase for 1–17 year olds, 152 percent increase for 45–64 year olds, 109 percent increase for 65–84 year olds, and 135 percent increase for patients 85 and older.

## EXHIBIT 3.3 Most Frequent All-listed Procedures by Gender

Procedures were performed in 62 percent of the discharges for both males and females in 2006. In the remaining 38 percent of discharges, no procedures were performed during the hospitalizations.

For males:

- Six percent of male discharges were newborns who underwent routine procedures such as circumcision, vision and hearing (ophthalmologic and otologic) diagnosis and treatment, and/ or vaccinations.
- Another 3 percent of male hospitalizations, also for newborns, received newborn procedures as well as other procedures not normally received at birth, such as respiratory intubation.
- The remaining 52 percent of discharges were not part of a newborn stay and had at least one procedure performed.

For females:

- Some of the most common procedures, performed in 21 percent of female discharges, took place during a childbirth or newborn stay.
  - Eight percent of female discharges received only procedures commonly performed for childbirth or as a newborn. In addition to the newborn procedures, these included maternal procedures such as episiotomy, Cesarean section, and fetal monitoring.
  - Another 13 percent of discharges involved a maternal or newborn procedure, and also involved at least one procedure not routinely performed during childbirth or on newborns, such as blood transfusion.
- The remaining 41 percent of female hospitalizations were not childbirth or newborn related. During each of these stays, one or more non-childbirth or non-newborn related procedures were performed.

Percent of Discharges With and Without Procedures by Gender, 2006

Number of Discharges, Percent Distribution, and Rank of the Most Frequent All-listed Procedures for Inpatient Hospital Stays Excluding Pregnancy and Childbirth, by Gender, 2006

ALL-LISTED CCS PROCEDURES | NUMBER OF DISCHARGES IN THOUSANDS | | PERCENT OF DISCHARGES WITH A PROCEDURE | | RANK
ALL-LISTED CCS PROCEDURES | MALES | FEMALES | MALES | FEMALES | MALES | FEMALES
Discharges with a procedure^†^ | 8,999 | 12,476 | 100% | 100%
Blood transfusion | 1,024 | 1,358 | 11 | 11 | 1 | 1
Diagnostic cardiac catheterization, coronary arteriography (diagnostic procedure to explore the functioning of the heart) | 1,017 | 654 | 11 | 5 | 2 | 3
Respiratory intubation and mechanical ventilation | 690 | 603 | 8 | 5 | 3 | 4
PTCA (percutaneous transluminal coronary angioplasty, procedure involving use of a balloon-tipped catheter to enlarge a narrowed artery) | 599 | 308 | 7 | 2 | 4 | 13
Upper gastrointestinal endoscopy (procedure to view and biopsy the esophagus, stomach and first portion of intestine through a lighted tube) | 547 | 666 | 6 | 5 | 5 | 2
Hemodialysis (dialysis, cleaning the blood by means of a machine or filter to compensate for poor kidney function) | 397 | 369 | 4 | 3 | 6 | 8
Echocardiogram (diagnostic ultrasound of heart) | 376 | 346 | 4 | 3 | 7 | 12
Alcohol and drug rehabilitation/detoxification | 275 | 116 | 3 | 1 | 8 | 37
Enteral and parenteral nutrition | 265 | 269 | 3 | 2 | 9 | 17
Colonoscopy and biopsy | 249 | 357 | 3 | 3 | 10 | 9
Arthroplasty knee | 205 | 346 | 2 | 3 | 17 | 11
Hysterectomy (removal of the uterus) | – | 549 | – | 4 | – | 5
Oophorectomy, unilateral and bilateral (removal of an ovary or ovaries) | – | 407 | – | 3 | – | 6

† Excludes procedures related to pregnancy and childbirth and a small number of discharges (less than 103,000 or 0.3 percent) with missing gender.

Hysterectomy and Oophorectomy All-listed Procedures, 1997–2006

Most procedures unrelated to childbirth and newborns are the same for both males and females.

- Blood transfusions were the most common procedure for both genders when childbirth and newborn procedures are excluded. Transfusions occurred in 11 percent of all procedure-related stays for both males and females.
- For procedures common to both males and females, some procedures occurred more frequently in one gender:
  - Two heart-related procedures—diagnostic cardiac catheterization and PTCAs—were performed more often on males than females, with those procedures totaling 1.6 million for males and 1.0 million for females.
  - In addition, males were more likely to receive respiratory intubation and mechanical ventilation and alcohol and drug rehabilitation/detoxification.
  - Females received blood transfusions, upper gastrointestinal endoscopy, colonoscopy and biopsy, and arthroplasty of the knee more often than males.
  - For all other top ranking procedures (hemodialysis, echo-cardiograms, and enteral and parenteral nutrition), there was little difference between males and females in the volume of procedures performed.
- Hysterectomy (removal of the uterus) and oophorectomy (removal of an ovary or ovaries) were the fifth and sixth most common procedures for females.
  - Both hysterectomy and oophorectomy procedures increased from 1997 to 2002.
  - Between 2002 and 2006, however, hysterectomies performed in hospitals declined 17 percent and oophorectomies fell by 23 percent.