# INPATIENT HOSPITAL STAYS BY DIAGNOSIS

## EXHIBIT 2.1 Most Frequent Principal Diagnoses

Number of Discharges, Percent Distribution, Rank, and Growth of the Most Frequent Principal Diagnoses for Inpatient Hospital Stays, 1997, 2005, and 2006

PRINCIPAL CCS DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | | | PERCENT OF DISCHARGES | | | RANK | | | GROWTH
PRINCIPAL CCS DIAGNOSIS | 1997 | 2005 | 2006 | 1997 | 2005 | 2006 | 1997 | 2005 | 2006 | 1997–2006
All discharges | 34,679 | 39,164 | 39,450 | 100.0% | 100.0% | 100.0% | | | | 14%
Pregnancy, childbirth, and newborn infants | 8,236 | 9,145 | 9,252 | 23.7 | 23.4 | 23.5 | 1 | 1 | 1 | 12
Pneumonia | 1,232 | 1,355 | 1,218 | 3.6 | 3.5 | 3.1 | 3 | 2 | 2 | −1
Coronary atherosclerosis (coronary artery disease) | 1,407 | 1,110 | 1,198 | 4.1 | 2.8 | 3.0 | 2 | 3 | 3 | −15
Congestive heart failure | 991 | 1,090 | 1,099 | 2.9 | 2.8 | 2.8 | 4 | 4 | 4 | 11
Non-specific chest pain | 538 | 825 | 857 | 1.6 | 2.1 | 2.2 | 10 | 5 | 5 | 59
Cardiac dysrhythmias (irregular heart beat) | 572 | 697 | 749 | 1.7 | 1.8 | 1.9 | 8 | 8 | 6 | 31
Osteoarthritis (degenerative joint disease) | 418 | 738 | 735 | 1.2 | 1.9 | 1.9 | 17 | 6 | 7 | 76
Mood disorders (depression and bipolar disorders) | 641 | 713 | 729 | 1.8 | 1.8 | 1.8 | 6 | 7 | 8 | 14
Acute myocardial infarction (heart attack) | 732 | 662 | 675 | 2.1 | 1.7 | 1.7 | 5 | 9 | 9 | −8
Disorders of intervertebral discs and bones in spinal column (back problems) | 536 | 647 | 636 | 1.5 | 1.7 | 1.6 | 11 | 10 | 10 | 19
Complication of device, implant or graft | 491 | 616 | 634 | 1.4 | 1.6 | 1.6 | 12 | 12 | 11 | 29
Septicemia (blood infection) | 413 | 538 | 611 | 1.2 | 1.4 | 1.5 | 18 | 15 | 12 | 48
Chronic obstructive lung disease | 551 | 630 | 598 | 1.6 | 1.6 | 1.5 | 9 | 11 | 13 | 8
Skin and subcutaneous tissue infections | 330 | 582 | 597 | 1.0 | 1.5 | 1.5 | 24 | 13 | 14 | 81
Acute cerebrovascular disease (stroke) | 616 | 526 | 537 | 1.8 | 1.3 | 1.4 | 7 | 17 | 15 | −13

In 2006, there were 39.5 million hospital stays, an increase of 14 percent since 1997. The 15 most frequently occurring principal diagnoses accounted for just over half of all discharges in 2006. Twelve of the 15 most frequent principal diagnoses in 2006 were among the most frequent diagnoses in 1997.

Among all discharges:

- Conditions related to pregnancy, childbirth, and newborn infants were by far the most frequent reason for hospitalizations, accounting for 23.5 percent of discharges (nearly one in four) in 2006, and were unchanged in rank across the years.
- Pneumonia and coronary artery disease (coronary atherosclerosis) were the second and third most common principal diagnoses, at 3.1 percent and 3.0 percent of discharges in 2006, respectively.
- Circulatory diseases accounted for 6 of the top 15 most frequent principal diagnoses in 2006.
  - The volume of stays for congestive heart failure, non-specific chest pain, and irregular heart beat increased between 1997 and 2006.
  - The volume of stays for coronary artery disease (coronary atherosclerosis), heart attacks, and stroke remained statistically unchanged or declined over the same period.
- The number of hospitalizations grew rapidly between 1997 and 2006 for some conditions:
  - Skin and subcutaneous tissue infections were up 81 percent and septicemia increased by 48 percent.
  - Degenerative joint disease (osteoarthritis) increased by 76 percent.
  - Non-specific chest pain rose by 59 percent. Many patients admitted to evaluate possible heart attack receive this diagnosis when the source of the pain cannot be determined.

Number of Discharges, Percent Distribution, Rank, and Growth of the Most Frequent Principal Diagnoses for Maternal and Infant Inpatient Hospital Stays, 1997, 2005, and 2006

PRINCIPAL CCS DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | | | PERCENT OF DISCHARGES | | | RANK | | | GROWTH
PRINCIPAL CCS DIAGNOSIS | 1997 | 2005 | 2006 | 1997 | 2005 | 2006 | 1997 | 2005 | 2006 | 1997–2006
All maternal discharges^*^ | 4,338 | 4,716 | 4,796 | 100.0% | 100.0% | 100.0% | | | | 11%
Trauma to external female genitals (vulva) and area between anus and vagina (perineum) due to childbirth | 713 | 784 | 818 | 16.4 | 16.6 | 17.1 | 1 | 1 | 1 | 15
Previous C-section | 271 | 481 | 505 | 6.3 | 10.2 | 10.5 | 3 | 2 | 2 | 86
Normal pregnancy and/or delivery | 544 | 325 | 315 | 12.5 | 6.9 | 6.6 | 2 | 3 | 3 | −42
Prolonged pregnancy | § | 234 | 242 | § | 5.0 | 5.0 | § | 6 | 4 | §
Early or threatened labor | 261 | 236 | 239 | 6.0 | 5.0 | 5.0 | 4 | 4 | 5 | −9
Hypertension complicating pregnancy, childbirth and the puerperium (high blood pressure during pregnancy) | 185 | 220 | 225 | 4.3 | 4.7 | 4.7 | 7 | 7 | 6 | 22
Fetal distress and abnormal forces of labor | § | 234 | 223 | § | 5.0 | 4.6 | § | 5 | 7 | §
Umbilical cord complication | 259 | 217 | 220 | 6.0 | 4.6 | 4.6 | 5 | 8 | 8 | −15
Polyhydramnios and other problems of amniotic cavity (excess amniotic fluid and other problems of amniotic cavity) | 202 | 191 | 190 | 4.7 | 4.1 | 4.0 | 6 | 9 | 9 | −6
All infant discharges | 3,898 | 4,429 | 4,456 | 100.0% | 100.0% | 100.0% | | | | 14%
Liveborn (newborn infant) | 3,777 | 4,228 | 4,289 | 96.9 | 95.5 | 96.2 | 1 | 1 | 1 | 14
Other perinatal conditions (other conditions occurring around the time of birth) | 56 | 94 | 82 | 1.4 | 2.1 | 1.8 | 2 | 2 | 2 | 46
Hemolytic jaundice and perinatal jaundice (infant jaundice following birth) | 33 | 57 | 46 | 0.8 | 1.3 | 1.0 | 3 | 3 | 3 | 40
Short gestation, low birth weight, and fetal growth retardation (premature birth and low birth weight) | 22 | 31 | 26 | 0.6 | 0.7 | 0.6 | 4 | 4 | 4 | 15
Infant respiratory distress syndrome | 8 | 16 | 12 | 0.2 | 0.4 | 0.3 | 5 | 5 | 5 | 46
Birth trauma | 1 | 1 | 1 | 0.0 | 0.0 | 0.0 | 7 | 6 | 6 | 10
Intrauterine hypoxia and birth asphyxia (lack of oxygen to baby in uterus or during birth) | 1 | 1 | 1 | 0.0 | 0.0 | 0.0 | 6 | 7 | 7 | −32

* Includes additional maternal CCS diagnoses not shown on this table but listed in the Sources and Methods of this report.

§ Consistent data is not available for this diagnosis due to coding changes that took place between 1997 and 2005.

There were 4.8 million maternal discharges in 2006, an 11-percent increase since 1997. Not all of these maternal discharges involved the birth of an infant; some dealt with complications during pregnancy. There were also 4.5 million infant discharges, a 14-percent increase since 1997.^1^

1 Only principal diagnoses (the main reason for the hospital stay) are listed in this exhibit. The table provides information on the number of discharges, assigning one diagnosis to each hospital stay based on the principal diagnosis. The number of cases and growth rates for specific maternal and infant conditions may differ from those shown in Exhibit 5.1, which shows all-listed diagnoses (principal plus all secondary conditions) for childbirth and newborn stays.

Among maternal discharges:

- Stays for normal pregnancy declined by 42 percent from 1997 to 2006. More maternal stays in 2006 had a principal diagnosis that indicated some problem in pregnancy or delivery than in 1997.
- The principal diagnosis of previous C-section increased 86 percent between 1997 and 2006.
- Stays with a principal diagnosis of high blood pressure during pregnancy increased by 22 percent between 1997 and 2006.
- Declines were seen for: umbilical cord complications (−15 percent), early or threatened labor (−8 percent), and excess amniotic fluid and other problems of the amniotic cavity (−6 percent).

Among infant discharges:

- Almost all infant discharges in 2006 (96 percent) had a principal diagnosis of “newborn infant.”
- Some conditions such as infant jaundice and infant respiratory distress syndrome increased 40 percent or more between 1997 and 2006.

## EXHIBIT 2.2 Most Frequent Principal Diagnoses by Age

Number of Discharges, Percent Distribution, and Growth of the Most Frequent Principal Diagnoses for Inpatient Hospital Stays by Age, 1997, 2005, and 2006

AGE GROUP AND PRINCIPAL CCS DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | | | PERCENT OF AGE-SPECIFIC TOTAL DISCHARGES | | | GROWTH
AGE GROUP AND PRINCIPAL CCS DIAGNOSIS | 1997 | 2005 | 2006 | 1997 | 2005 | 2006 | 1997–2006
All ages, total discharges^†^ | 34,679 | 39,164 | 39,450 | | | | 14%
< 1 year, total discharges | 4,426 | 4,978 | 4,908 | 100.0% | 100.0% | 100.0% | 11
Liveborn (newborn infant) | 3,776 | 4,223 | 4,284 | 85.3 | 84.8 | 87.3 | 13
Acute bronchitis | 108 | 107 | 102 | 2.4 | 2.2 | 2.1 | −6
Hemolytic jaundice and perinatal jaundice (infant jaundice following birth) | 33 | 56 | 46 | 0.7 | 1.1 | 0.9 | 40
Pneumonia | 55 | 43 | 39 | 1.3 | 0.9 | 0.8 | −29
Short gestation, low birth weight, and fetal growth retardation (premature birth and low birth weight) | 22 | 31 | 26 | 0.5 | 0.6 | 0.5 | 15
1–17 years, total discharges | 1,821 | 2,059 | 1,711 | 100.0 | 100.0 | 100.0 | −6
Asthma | 159 | 139 | 122 | 8.7 | 6.8 | 7.1 | −23
Pneumonia | 135 | 142 | 116 | 7.4 | 6.9 | 6.8 | −14
Appendicitis and other appendiceal conditions | 65 | 90 | 80 | 3.6 | 4.3 | 4.7 | 23
Fluid and electrolyte disorders (primarily dehydration or fluid overload) | 64 | 98 | 74 | 3.5 | 4.8 | 4.3 | 15
Mood disorders (depression and bipolar disorders) | 64 | 73 | 62 | 3.5 | 3.6 | 3.6 | −3
18–44 years, total discharges | 9,444 | 10,041 | 10,212 | 100.0 | 100.0 | 100.0 | 8
Trauma to external female genitals (vulva) and area between anus and vagina (perineum), due to childbirth | 676 | 753 | 785 | 7.2 | 7.5 | 7.7 | 16
Previous C-section | 270 | 478 | 502 | 2.9 | 4.8 | 4.9 | 86
Mood disorders (depression and bipolar disorders) | 335 | 364 | 375 | 3.5 | 3.6 | 3.7 | 12
Normal pregnancy and/or delivery | 511 | 312 | 303 | 5.4 | 3.1 | 3.0 | −41
Prolonged pregnancy | § | 224 | 231 | § | 2.2 | 2.3 | §
45–64 years, total discharges | 6,496 | 8,660 | 9,100 | 100.0% | 100.0% | 100.0% | 40%
Coronary atherosclerosis (coronary artery disease) | 526 | 461 | 501 | 8.1 | 5.3 | 5.5 | −5
Non-specific chest pain | 242 | 388 | 408 | 3.7 | 4.5 | 4.5 | 69
Osteoarthritis (degenerative joint disease) | 105 | 272 | 281 | 1.6 | 3.1 | 3.1 | 167
Disorders of intervertebral discs and bones in spinal column (back problems) | 190 | 266 | 269 | 2.9 | 3.1 | 3.0 | 42
Pneumonia | 199 | 271 | 260 | 3.1 | 3.1 | 2.9 | 31
65–84 years, total discharges | 10,121 | 10,449 | 10,512 | 100.0 | 100.0 | 100.0 | 4
Coronary atherosclerosis (coronary artery disease) | 741 | 541 | 584 | 7.3 | 5.2 | 5.6 | −21
Congestive heart failure | 581 | 571 | 559 | 5.7 | 5.5 | 5.3 | −4
Pneumonia | 514 | 550 | 494 | 5.1 | 5.3 | 4.7 | −4
Osteoarthritis (degenerative joint disease) | 281 | 419 | 406 | 2.8 | 4.0 | 3.9 | 44
Cardiac dysrhythmias (irregular heart beat) | 333 | 366 | 392 | 3.3 | 3.5 | 3.7 | 18
85+ years, total discharges | 2,362 | 2,926 | 2,970 | 100.0 | 100.0 | 100.0 | 26
Congestive heart failure | 202 | 244 | 250 | 8.6 | 8.4 | 8.4 | 24
Pneumonia | 197 | 231 | 203 | 8.3 | 7.9 | 6.8 | 3
Fracture of neck of femur (hip fracture) | 125 | 123 | 119 | 5.3 | 4.2 | 4.0 | −5
Septicemia (blood infection) | 76 | 103 | 115 | 3.2 | 3.5 | 3.9 | 51
Urinary tract infections | 75 | 111 | 114 | 3.2 | 3.8 | 3.9 | 53

† Includes a small number of discharges (less than 38,000 or 0.1 percent) with missing age.

§ Consistent data is not available for this diagnosis due to coding changes that took place between 1997 and 2005.

The top five principal diagnoses for hospitalizations generally varied by age. Older patients were more frequently admitted with cardiovascular and musculoskeletal conditions and younger patients were more frequently admitted with pregnancy- and childbirth-related conditions. The largest increase in hospitalizations occurred for 45–64 year olds (up 40 percent) and adults 85 and older (up 26 percent).

- Pneumonia was a top five condition for all age groups except 18–44 year olds in 1997–2006.
- Asthma and pneumonia were the most common reasons for hospital admission among children ages 1–17 in 1997–2006.
- Depression and bipolar disorders (mood disorders) were among the most common diagnoses for children ages 1–17 and adults ages 18–44 in 1997–2006.
- Of the most frequent diagnoses for adults ages 18–44, all except one (mood disorders) were related to pregnancy and delivery in 1997–2006.
- Cardiovascular conditions were the most common diagnoses for adults ages 45 and above. However, specific diagnoses differed somewhat between age groups for older adults:
  - Coronary atherosclerosis (coronary artery disease) was the most frequent cardiac condition for adults ages 45–64 in 1997, 2005, and 2006 and for ages 65–84 in 1997 and 2006.
  - Congestive heart failure was the most common cardiac condition for adults 85 years and older in 1997–2006.
- Degenerative joint disease (osteoarthritis) was a common diagnosis for adults ages 45–64 and ages 65–84 in 2006; it increased by 167 percent among adults ages 45–64 and by 44 percent among adults ages 65–84 between 1997 and 2006.
- Hospital stays for hip fractures, a common diagnosis among adults 85 and over, changed very little between 1997 and 2006.
- Among adults 85 and over, hospitalizations for septicemia (up 51 percent) and urinary tract infections (up 53 percent) increased at twice the rate of all hospitalizations for this age group between 1997 and 2006.

## EXHIBIT 2.3 Most Frequent Principal Diagnoses by Gender

Number of Discharges, Percent Distribution, and Rank of the Most Frequent Principal Diagnoses for Inpatient Hospital Stays by Gender, 2006

PRINCIPAL CCS DIAGNOSIS | MALES | | | FEMALES | | | PERCENT OF PRINCIPAL DIAGNOSIS TOTAL DISCHARGES
PRINCIPAL CCS DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | PERCENT OF MALE DISCHARGES | RANK | NUMBER OF DISCHARGES IN THOUSANDS | PERCENT OF FEMALE DISCHARGES | RANK | MALES | FEMALES
All diagnoses^†^ | 16,296 | 100.0% | | 23,052 | 100.0% | | 41% | 59%
Pregnancy and childbirth | | | | 4,785 | 20.8 | 1
Liveborn (newborn infant) | 2,191 | 13.4 | 1 | 2,090 | 9.1 | 2 | 51 | 49
Coronary atherosclerosis (coronary artery disease) | 747 | 4.6 | 2 | 451 | 2.0 | 6 | 62 | 38
Pneumonia | 583 | 3.6 | 3 | 633 | 2.7 | 3 | 48 | 52
Congestive heart failure | 534 | 3.3 | 4 | 565 | 2.4 | 4 | 49 | 51
Acute myocardial infarction (heart attack) | 406 | 2.5 | 5 | 269 | 1.2 | 20 | 60 | 40
Non-specific chest pain | 379 | 2.3 | 6 | 477 | 2.1 | 5 | 44 | 56
Cardiac dysrhythmias (irregular heart beat) | 369 | 2.3 | 7 | 379 | 1.6 | 10 | 49 | 51
Complication of medical device, implant or graft | 327 | 2.0 | 8 | 307 | 1.3 | 16 | 52 | 48
Skin and subcutaneous tissue infections | 319 | 2.0 | 9 | 276 | 1.2 | 19 | 54 | 46
Mood disorders (depression and bipolar disorders) | 310 | 1.9 | 10 | 418 | 1.8 | 8 | 43 | 57
Osteoarthritis (degenerative joint disease) | 281 | 1.7 | 13 | 451 | 2.0 | 7 | 38 | 62
Urinary tract infections | 149 | 0.9 | 28 | 382 | 1.7 | 9 | 28 | 72

† Excludes a small number of discharges (less than 103,000 or 0.3 percent) with missing gender.

The top ten most frequent conditions for men and women in the hospital were responsible for almost 40 percent of all stays for men and 50 percent of all stays for women. Most diagnoses are common to both males and females, if those related to childbirth are excluded. However, some diagnoses were more frequent in one gender.

- Females accounted for almost 6 out of every 10 hospital stays—23.1 million stays in 2006. About 21 percent of all female hospitalizations were related to pregnancy and childbirth.
- Males accounted for 16.3 million hospitalizations in 2006.
- Five heart-related diagnoses—coronary artery disease, congestive heart failure, heart attacks, non-specific chest pain, and cardiac dysrhythmias—were among the ten most common principal diagnoses for both male and female hospitalizations.
  - Coronary artery disease and heart attacks were responsible for more male than female hospitalizations in 2006. Males accounted for 62 percent of hospital stays for coronary artery disease and 60 percent of stays for heart attack.
  - Congestive heart failure (534,000 stays for males and 565,000 for females) and irregular heart beat (369,000 stays for males and 379,000 for females) occurred equally often in hospitalizations for males and females.
  - Non-specific chest pain was more often the reason for hospitalization for women (56 percent of stays) than for men (44 percent of stays).
- Other conditions causing many more hospitalizations for females than males included mood disorders (57 percent female), degenerative joint disease (62 percent female) and urinary tract infections (72 percent female).
- Other conditions causing more hospitalizations for males than females included skin and subcutaneous tissue infections (54 percent male).