# OVERVIEW STATISTICS FOR INPATIENT HOSPITAL STAYS

## EXHIBIT 1.1 Characteristics of U.S. Hospitals

Characteristics of U.S. Community Hospitals, 1997, 2005, and 2006

UTILIZATION, CHARGES, AND COSTS | 1997 | 2005 | 2006
Discharges:
Total discharges in millions | 34.7 | 39.2 | 39.5
Discharges per 1,000 population^*^ | 127.8 | 132.1 | 131.9
Total days of care in millions | 168.1 | 181.5 | 181.3
Average length of stay in days | 4.8 | 4.6 | 4.6
Percent of discharges from:
Metropolitan hospitals | 84% | 87% | 87%
Hospital ownership:
Non-Federal government hospitals | 14% | 14% | 14%
Private not-for-profit hospitals | 73% | 72% | 72%
Private for-profit hospitals | 13% | 14% | 14%
Charges and costs^†^
Charges:
Average charges per stay | $11,300 | $22,300 | $24,000
Average inflation-adjusted charges per stay in 2006 dollars^‡^ | $13,800 | $23,000 | $24,000
Costs:
Total aggregate costs in billions | $177.1 | $316.3 | $329.2
Average costs per stay | $5,100 | $8,100 | $8,400
Inflation-adjusted costs in 2006 dollars:^‡^
Total aggregate costs in billions | $216.3 | $326.3 | $329.2
Average costs per stay | $6,200 | $8,300 | $8,400

* Calculated using population from the U.S. Bureau of the Census (http://www.census.gov/popest/national/asrh/2006_nat_res.html).

† Charges represent amounts billed by hospitals. These amounts are seldom paid in full by insurers. Costs are calculated from charges using reported cost-to-charge ratios calculated from information on Medicare Cost Reports, reported by hospitals to the Centers for Medicare and Medicaid Services (CMS).

‡ Adjusted for inflation using the GDP deflator (http://www.bea.gov/national/nipaweb/SelectTable.asp#S1, Table 1.1.4 Price Indexes for Gross Domestic Product).

The volume of discharges changed little and increases in inpatient hospital costs slowed in 2006.

- Of the 5,747 registered hospitals in the U.S. in 2006, 4,927 (86 percent) were community hospitals, down from 5,060 in 1997.^1^
  1 Fast Facts on US Hospitals. Online. October 23, 2007. American Hospital Association. http://www.aha.org/aha/resource-center/Statistics-and-Studies/fast-facts.html.
- The volume of discharges, 39.5 million in 2006, changed little from the level in 2005, as did discharges per 1,000 population (131.9) and days of care (181.3 million).
- The percent of community hospital discharges was relatively stable in terms of metropolitan location and ownership between 1997 and 2006.
- The average charge for the typical stay at a U.S. community hospital rose from $11,300 in 1997 to $24,000 in 2006, an increase of 8.7 percent per year. Few patients or insurers paid those amounts because of discounts negotiated with hospitals.
- The aggregate costs for stays in community hospitals rose between 1997 and 2006, from $177.1 billion to $329.2 billion—an average annual increase of 7.1 percent.
  - Almost one-third of the cost increase was due to inflation, 16 percent to population growth, and 5 percent to the increased number of hospitalizations per person (measured as discharges per population).
  - The remainder (47 percent) was attributable to greater intensity in the use of services.
- The cost growth from 2005 to 2006 was slow (just 4.1 percent) in comparison to the annual growth in costs over the 1997–2005 period (7.5 percent).
- After costs were adjusted for general inflation, the total cost for hospital stays nationwide rose 5.3 percent per year from 1997 to 2005, but by only 0.9 percent from 2005 to 2006.

## EXHIBIT 1.2 Inpatient Hospital Stays and Average Length of Stay

Number of Inpatient Stays and Average Length of Stay, 1993–2006

The average length of stay in U.S. community hospitals stabilized beginning in 2000, while the number of hospital stays continued to slowly rise.

- The average length of stay (ALOS) in 2006 was 4.6 days—almost 20 percent shorter than in 1993, when the ALOS was 5.7 days. The ALOS declined throughout most of the 1990s and has remained unchanged in the current decade at 4.6 days.
- The number of discharges increased from 34.3 million in 1993 to 39.5 million in 2006.
- There were about 132 hospital stays for every 1,000 persons in the United States in 2006, approximately the same number as in 1993.
- From 1993 to 1998, the number of discharges grew very slowly, increasing by only 0.6 million.
  - Growth in the number of discharges (an average of 0.3 percent annually) did not keep pace with the growth in population (1.2 percent annually).
  - It is likely that rapid growth in the adoption of managed care plans and the shift to outpatient (ambulatory) care slowed growth in inpatient hospital utilization.
- However, from 1998 through 2005, the number of discharges rose by 4.3 million.^2^ Growth in the number of discharges (an average of 1.6 percent annually) exceeded population growth (1.1 percent annually).
  2 From 1998 to 2001, low unemployment and the need for employers to attract and retain workers through generous health benefits produced a loosening of care management by insurance plans. Forrest S, Goetghebeur M, Hay J. Forces Influencing Inpatient Hospital Costs in the United States. Online. October 16, 2002. Available at http://www.bcbs.com/blueresources/cost/3_Inpatient_Lit_Review.pdf.
- The number of discharges between 2005 and 2006 rose just 0.7 percent, slower than the growth in population (0.9 percent).

## EXHIBIT 1.3 Reasons for Hospital Stays

Distribution of Discharges by Major Reason* for Hospital Stay, 2006

* Based on principal diagnosis defined by Major Diagnostic Categories (MDCs).

- Circulatory conditions were the most frequent major cause of hospital stays in 2006, accounting for 16 percent of all hospital stays. These stays were for diagnoses such as coronary artery disease, congestive heart failure, heart attack, and irregular heart beat.
- Pregnancy and childbirth (12 percent) and newborns (11 percent) ranked second and third among reasons for hospitalizations and, combined, were responsible for one out of four stays in hospitals.
- Together with respiratory conditions (10 percent of all discharges) and digestive conditions (9 percent of all discharges), the top five major reasons for hospital stays accounted for 58 percent of all discharges.
- Males accounted for 16.3 million stays in 2006 or 41 percent of all hospitalizations.
  - Of these stays, 21 percent were for circulatory conditions, 14 percent were for newborns, 11 percent were for respiratory conditions, and 9 percent involved conditions of the digestive system.
  - These four major conditions amounted to 55 percent of all hospitalizations for males.
- Females experienced 23.1 million hospitalizations in 2006, or 6.8 million more stays than males. About 59 percent of all hospitalizations involved females.
  - Even when pregnancy and childbirth stays are excluded, females accounted for more stays than males—18.3 million stays for females compared to 16.3 million stays for males.
  - Pregnancy and childbirth was the reason for 2 out of every 10 female hospitalizations.
  - About 9 percent of female stays in the hospital were newborns.
  - Other major reasons for female hospitalizations were related to the circulatory system (13 percent), respiratory system (9 percent), and digestive system (8 percent).
- If pregnancy and childbirth are excluded, the largest differences between males and females in reasons for hospitalization were for diseases of the circulatory system, which accounted for 3.4 million male hospital stays, but only 3.0 million female stays, and diseases of the digestive system, which accounted for 1.9 million female stays, but only 1.5 million male stays.

Hospital Stays for Males and Females by Major Reason,* 2006

## EXHIBIT 1.4 Expected Primary Payer

Percent Distribution of Discharges by Expected Primary Payer, 2006

* Includes other payers such as Workers’ Compensation, TRICARE, CHAMPUS, CHAMPVA, Title V, and other government programs.

** Includes discharges classified as self-pay or no charge.

The expected primary payer bears the major financial responsibility for the hospital stay. However, other payers, including the patients themselves, may also pay part of the cost of hospitalization.

- Medicare and Medicaid together assumed primary financial responsibility for 57 percent of all hospital stays in 2006.
  - Medicare was the expected primary payer for 37 percent of all inpatient hospital discharges (14.7 million hospital stays). Medicare patients are 65 and older or disabled.
  - Medicaid was the expected primary payer for 1 out of every 5 hospital stays (20 percent or 7.7 million discharges). These may include stays for patients covered by the State Children’s Health Insurance Program (SCHIP), depending on the state in which the hospital was located.
- Private insurance was the expected primary payer for 34 percent of all discharges (13.4 million hospital stays). These stays were primarily for employed persons and their families who receive health insurance coverage through their employers.
- Approximately 6 percent of all stays (2.2 million discharges) were listed as uninsured.
- Other payers accounted for 3 percent of all stays in 2006.

Growth in Number of Discharges by Expected Primary Payer, 1997–2006

Between 1997 and 2006, the number of hospital discharges grew by 14 percent; however, the growth varied widely by expected primary payer.

- Medicaid discharges grew by 36 percent and uninsured discharges grew at nearly the same rate—34 percent. These rates are more than twice the rate of growth of all discharges.
- The number of discharges for which Medicare was the primary payer grew at close to the same rate as the all-payer discharge rate (17 percent for Medicare and 14 percent for all discharges).
- The number of discharges covered primarily by private insurance did not change between 1997 and 2006.

## EXHIBIT 1.5 Admission Source

Distribution of Discharges by Admission Source, 1997–2006

* Includes admissions from other hospitals, from long-term care, and from court or law enforcement.

Admission source indicates routine admission and other specific settings where the patient was located prior to admission to the hospital.

- The majority of hospital admissions were routine—non-emergency admissions from home, via a physician or clinic referral, or due to birth. However, these admissions made up a smaller share of all admissions by 2006 (51 percent) than they did in 1997 (56 percent).
- Emergency departments accounted for 38 percent of all hospital admissions in 1997. By 2002 these admissions accounted for 44 percent of all admissions, a share that remained relatively stable through 2006.
- The portion of admissions from other sources (short-term hospitals, long-term care facilities, court and other law enforcement facilities, and other sources) remained between 5 and 6 percent from 1997 through 2006.

## EXHIBIT 1.6 Discharge Status

Distribution of Inpatient Hospital Stays by Discharge Status, 2006

Discharge status indicates the circumstance surrounding the discharge or where the patient went after discharge from the hospital. Most discharges were routine in nature, but discharges to follow-on care were also frequent.

- The most common patient discharge status was routine (74 percent), with the patient being sent home without closely supervised health care.
- Discharge to a long-term care facility was the second most common type of discharge, accounting for 12 percent of discharges.
- Discharge to the home with home health care supervision accounted for 9 percent of discharges.
- Remaining discharge circumstances (in-hospital death, to another short-term hospital, or when the patient leaves against medical advice) each accounted for 2 percent or less of discharges.

Growth in Number of Hospital Stays by Discharge Status, 1997–2006

The number of discharges increased by 14 percent from 1997 to 2006, but growth varied by discharge status.

- The number of discharges to home health grew by 53 percent.
- The number of patients who left the hospital against medical advice, although small, rose by 48 percent—the second fastest increase of any discharge type.
- Discharges to nursing homes and long term care increased by 30 percent.
- The number of in-hospital deaths decreased by 5 percent.

Percent Distribution of Routine Discharges and Discharges Against Medical Advice by Payer, 2006

* Includes discharges classified as self-pay or no charge.

** Includes other payers such as Workers’ Compensation, TRICARE, CHAMPUS, CHAMPVA, Title V, and other government programs.

Compared with routine discharges, hospital stays that ended in a discharge against medical advice had a different distribution of expected payers.

- Only 18 percent of patients discharged against medical advice were privately insured, compared to 40 percent of routine discharges.
- Persons discharged against medical advice were more likely to be uninsured or to have Medicaid as their primary expected payer than those who were discharged routinely.
  - About 21 percent of patients discharged against medical advice were uninsured, compared to 7 percent of routine discharges.
  - Similarly, 32 percent of patients discharged against medical advice were covered by Medicaid, compared to 23 percent of routine discharges.
- There was no difference in the distribution of Medicare and other payer discharges between patients who were discharged routinely and those who were discharged against medical advice.

## EXHIBIT 1.7 Patient Age

Distribution of U.S. Population and Hospital Discharges by Age, 2006

Note: Bar segments representing 2 percent or less have not been labeled.

Older people account for a disproportionately larger share of hospitalizations compared to other age groups.

- While people ages 65 and older represented 13 percent of the population in 2006, they comprised 34 percent of the hospitalizations.
- The younger patient age groups had a lower proportion of hospitalizations relative to their representation in the population.
  - Patients 18–64 years of age, at 63 percent of the population, accounted for 49 percent of hospitalizations.
  - Those under age 18, at 25 percent of the population, accounted for 17 percent of hospitalizations.

Discharges per 1,000 Population by Age, 2006

Discharges for an age group divided by the number of people in that age group (discharges per 1,000 population) show that older age is associated with a greater chance of hospitalization.

- Across all age groups, there were an average of 132 discharges for every 1,000 persons in the United States in 2006.
- While there were only 25 hospital stays for every 1,000 children ages 1 to 17 in 2006, there were 560 stays for every 1,000 adults ages 85 and above.
- The one exception to this pattern was for infants younger than 1 year of age. This group experienced 1,187 hospitalizations per 1,000 infants, because nearly all births occur in the hospital and some infants require additional hospitalization in the first year of life.