# INTRODUCTION

Accurate and reliable hospital information is of vital importance—for a researcher investigating treatment outcomes, for a newly-diagnosed patient seeking information on the frequency with which procedures are performed, or for hospital executives researching medical trends to support purchasing decisions. The Healthcare Cost and Utilization Project (HCUP) can provide comprehensive information to help fulfill these and other needs.

Sponsored by the Agency for Healthcare Research and Quality (AHRQ), HCUP is a family of health care databases and related software tools and products developed through a Federal-State-Industry partnership, creating a national information resource of patient-level discharge health care data.

HCUP is only possible through the collective efforts of State and private data organizations, hospital associations, and the Federal government to create the single largest all-payer discharge record resource from hospitals in the U.S.—representing community, non-Federal, short-term (acute care) general and specialty hospitals. Data on conditions treated in the hospital, as well as information on medical and surgical procedures are included. HCUP data are ideal for analyzing treatment use and diagnostic trends, examining patient characteristics, conducting cost and charge studies, and investigating quality of care.

The most popular HCUP database is the Nationwide Inpatient Sample (NIS), the largest all-payer database in the U.S. The NIS contains all discharge records from a sample of more than 1,000 hospitals in HCUP-participating states. This broad-based collection of data provides information on patient and hospital demographics, diagnoses, procedures, charges, estimated costs, payers, source of admission and discharge status.

HCUP Facts and Figures highlights the rich potential of HCUP by providing targeted analysis of important trends organized around high-interest topics—hospital and discharge characteristics, diagnoses, procedures, costs, and charges. In the last section, we have focused on hospitalizations related to four of the priority health conditions designated by the Institute of Medicine (IOM) in its report, Priority Areas for National Action: Transforming Health Care Quality^1^; these are childbirth, depression, cancer, and asthma. This section also includes one condition—arthritis—which was chosen from among ten priority conditions designated by the U.S. Department of Health and Human Services that affect individuals covered by government programs.^2^ The conditions on both lists, including the five we present in this report, represent areas of greatest consequence for the patient population, affect a broad range of people, and offer the most important opportunities for quality improvement.

1 Committee on Identifying Priority Areas for Quality Improvement, Board of Health Care Services (2003). Priority Areas for National Action: Transforming Health Care Quality. Adams K and Corrigan JM (Ed). Washington, D.C.: Institute of Medicine (IOM).

2 Agency for Healthcare Research and Quality (2004). Press Release: List of Priority Conditions for Research under Medicare Modernization Act Released. December 15, 2004. http://www.ahrq.gov/news/press/pr2004/mmapr.htm

In documenting hospitalization trends, this report illustrates the range of information available from the HCUP NIS and its capacity to track the evolution of hospital use over time. Many of the statistics presented in this report are available online through HCUPnet (http://hcupnet.ahrq.gov/). Graphical presentations, statistical tables, and bulleted notes highlight key facts and emerging trends for each topic.

HCUP has been a leader in hospital data and products and continues to be on the forefront of health care research in the 21st century. For more information, please visit the HCUP website at http://www.hcup-us.ahrq.gov.