# HIGHLIGHTS

HCUP Facts and Figures, 2006: Statistics on Hospital-based Care in the United States presents information derived from the 2006 HCUP Nationwide Inpatient Sample (NIS), with trend information as far back as 1993. This report includes information from the 2006 database containing discharge records for all patients treated in a sample of approximately 1,000 hospitals. These discharges are weighted to represent all inpatient stays in community hospitals across the nation. Community hospitals include all non-federal, short-term, acute care hospitals; psychiatric and substance abuse facilities and short-term rehabilitation hospitals are not included.

## Overall Hospital Statistics

- In 2006, there were 39.5 million discharges from community hospitals, or 131.9 discharges per 1,000 population, about the same discharge rate as in 1993.
- Female discharges accounted for 59 percent of all discharges. Pregnancy and childbirth was the reason for two out of every ten female hospitalizations.
- While there were only 25 hospital stays for every 1,000 children ages 1 to 17, adults ages 85 and older registered 560 stays for every 1,000 persons in this oldest age group.
- Aggregate costs for stays in community hospitals rose an average of 7.1 percent annually between 1997 and 2006. Almost one-third of the cost increase was due to inflation, 16 percent to population growth, 5 percent to increased discharges per population, and 47 percent to greater intensity in the use of services during the hospital stay.
- After adjusting for general inflation, the total cost for hospital stays nationwide rose only 0.9 percent from 2005 to 2006, compared to an increase of 5.3 percent per year from 1997 to 2005.
- The number of discharges rose just 0.7 percent from 2005 to 2006, the slowest growth since 1998.
- The share of admissions through emergency departments increased from 38 percent in 1997 to 44 percent in 2002 through 2006.
- Between 1997 and 2006, the number of discharges to home health grew by 53 percent and to nursing homes by 30 percent. At the same time, the number of in-hospital deaths decreased by 5 percent.
- Persons discharged against medical advice were more likely to be uninsured (21 percent) or have Medicaid (32 percent) as their expected primary payer, compared to routinely discharged patients who were uninsured (7 percent) or were covered by Medicaid (23 percent).
- Medicaid discharges grew by 36 percent and uninsured discharges by 34 percent during the 1997–2006 period. There was no change in the number of discharges covered by private insurance and Medicare discharges grew by only 17 percent.

## Most Frequent Diagnoses

- Conditions related to pregnancy, childbirth, and infants accounted for nearly one out of every four discharges.
- Circulatory conditions were responsible for 16 percent of all hospital stays.
- Between 1997 and 2006, there were substantial increases in hospitalizations for skin and subcutaneous tissue infections (81 percent), blood infections (48 percent), degenerative joint disease (76 percent), and non-specific chest pain (59 percent). This compares to a 14 percent increase in all discharges.
- Pneumonia was a top five condition for all age groups except 18–44 year olds.

## Most Frequent Procedures

- Six out of ten hospital stays had a procedure associated with them.
- Blood transfusions occurred in one out of every ten hospital stays that included a procedure in 2006. Discharges with blood transfusions have increased 117 percent from 1997 to 2006, making this the largest as well as the fastest growing of the most common procedures performed during a hospital stay.
- Seven of the all-listed procedures that ranked among the top 10 in 1997, 2005 and/or 2006 were associated with giving birth and newborns. The number of stays with C-sections rose substantially (68 percent) between 1997 and 2006, while the stays in which episiotomies were performed declined by 55 percent.
- Discharges with a respiratory intubation and mechanical ventilation procedure rose steadily from 0.9 million in 1997 to 1.3 million in 2006—a 41 percent increase.
- Hysterectomy (removal of the uterus) and oophorectomy (removal of an ovary or ovaries) were the fifth and sixth most common procedures for females. Between 2002 and 2006, the number of discharges with these procedures declined by 17 percent and 23 percent, respectively.

## Spending for Hospitalization

- The top 20 principal diagnoses with the highest aggregate inpatient hospital costs represented 47 percent of the $329.2 billion total cost for all stays in U.S. community hospitals in 2006.
- Of the top 20 costliest inpatient diagnoses, blood infections (septicemia) showed the most dramatic increase in inflation-adjusted costs from 2003 to 2006, growing by 23.6 percent annually.
- The inflation-adjusted cost of hospitalizations for degenerative joint disease (osteoarthritis), blood infections, adult respiratory failure, back problems, non-specific chest pain, and skin and subcutaneous tissue infections at least doubled between 1997 and 2006.
- Six of the twenty most costly conditions were related to the circulatory system and accounted for 18 percent of all costs for hospitalization in 2006. These conditions included coronary artery disease, stroke, heart attack, congestive heart failure, irregular heart beat, and non-specific chest pain.
- The inflation-adjusted cost of these six circulatory conditions rose 5.8 percent annually from 1997 to 2003, but slowed to 0.5 percent annually from 2003 to 2006. The recent slowdown was mostly attributable to a decline in the number of discharges with these conditions that averaged almost 1 percent per year.
- Spinal cord injuries had the highest mean charge of any condition, $113,200, primarily due to the expensive technology and intensive care involved with these hospitalizations. Infant respiratory distress syndrome, with a mean charge of $106,500, ranked second, primarily due to the long average length of stay (23 days).

## Priority Conditions

The Institute of Medicine (IOM) and the U.S. Department of Health and Human Services (DHHS) have identified a number of priority conditions where important quality improvements in delivery of health care could increase effectiveness and efficiency. Five of the IOM and DHHS designated conditions are covered in this report.

### Childbirth and Newborns

#### Childbirth

- Of the 4.3 million maternal stays for infant deliveries in 2006, 68 percent represent vaginal deliveries, a noticeably smaller share of all deliveries than in 1993 (78 percent).
- Both first time C-sections and repeat C-sections grew rapidly—by 55 percent and 98 percent, respectively—between 1998 and 2006.
- Complications of maternal stays were more often listed for women undergoing C-section (rather than a vaginal delivery) and were often the rationale for performing C-sections.
- Complications due to hypertension, diabetes, and anemia were present in a higher proportion of C-section than vaginal deliveries.
- The largest decline in delivery complications was for C-section deliveries involving fetopelvic disproportion. This condition complicated 23 percent (190,000) of C-section deliveries in 1993, but only 10 percent (136,000) of these deliveries in 2006.

#### Newborns

- Between 1993 and 2006, the number of infant births grew from 3.8 million to 4.3 million. The number of infants delivered vaginally did not change during this period. However, the number of infants born by C-section increased by 0.6 million, or 69 percent, at an annual rate of 4 percent.
- In 2006, 1.4 million infants were delivered by C-section and 2.9 million infants were delivered vaginally. The most common complication experienced by newborns was jaundice—affecting 26 percent of C-section delivered infants, but only 16 percent of vaginally delivered infants.
- Thirteen percent of infants delivered by C-section (183,400) were premature, compared with 6 percent of vaginally delivered infants (168,600). Post-birth respiratory problems not elsewhere classified, transitory tachypnea and respiratory distress syndrome were each diagnosed in 4 to 7 percent of infants delivered by C-section, but in just 1 to 3 percent of infants born by vaginal delivery.
- Between 1993 and 2006, fetal distress during labor, premature rupture of membrane affecting newborn, and fetal and newborn aspiration declined among infants born both by C-section and vaginally. Other complications, including feeding problems and neonatal jaundice, increased among all infants.

### Depression

- In 2006, there were 423,000 hospital stays with a principal diagnosis of depression. Individuals ages 1–44 comprised a larger share of hospital stays for depression (57 percent) than they did of overall hospitalizations (35 percent).
- The most common secondary diagnosis among individuals ages 1–44 was substance abuse, which was diagnosed in 36 percent of these depression discharges.
- Patients living in the lowest income communities had a higher rate of hospitalization for depression (161 stays per 100,000 population) than persons in the highest income communities (112 stays per 100,000 population).
- The West, with 62 stays per 100,000 population, had the lowest rate of hospitalization for depression of any region—half the rate in the South and about one-third the rate in the Northeast and Midwest.

### Cancer

- There were 1.45 million hospitalizations for cancer in 2006, a decline of almost ten percent from 1997.
- Hospitalizations for lung cancer (200,000 discharges in 2006), the leading cause of cancer hospitalizations, decreased 10 percent between 1997 and 2006. Lung cancer was the top reason for cancer-related hospitalizations for men and the second for women.
- Breast cancer hospitalizations, the leading cause of cancer- related stays in women, declined by 32 percent between 1997 and 2006.
- There were also substantive decreases in the number of hospital stays for head and neck cancer (−17 percent), prostate cancer (−17 percent), bladder cancer (−20 percent), ovarian cancer (−30 percent), and cervical cancer (−39 percent).
- The prevalence of hospital stays for cancer was lowest in the West and highest in the Midwest.

### Asthma

- There were 420,900 hospitalizations for asthma in 2006. Six out of every ten hospital stays were for women and almost one-third were for children under the age of 18.
- The rate of hospital stays for asthma was generally higher for females than males, except among children ages 0–17 where the rate of hospitalization for males was 1.6 times the rate among females.
- The prevalence of hospital stays for asthma was greater in lower income communities than it was in middle and high income communities in all regions of the country.

### Arthritis

- The number of hospitalizations with a principal diagnosis of arthritis more than doubled between 1993 and 2006— from 362,600 to 754,000.
- Hospital stays for women accounted for 75 percent of stays with a principal diagnosis of rheumatoid arthritis and 62 percent of stays for osteoarthritis.
- Among those hospitalized for arthritis in 2006, 65 percent had knee arthroplasty, 26 percent had hip replacement, and 4 percent had arthroplasty other than hip or knee. These discharges accounted for 9 out of every 10 knee arthroplasties, 52 percent of all hip replacements, and 50 percent of all non-knee and non-hip arthroplasties.