# ACKNOWLEDGMENTS

Thanks to Eva Witt and Nils Nordstrand at Thomson Reuters for their programming support; Anne Pfuntner at Thomson Reuters for her assistance in the preparation of tables and text; Cheryl Kassed, also at Thomson Reuters, for her editorial assistance; and Robyn Short of The Madison Design Group for her creative design and layout of the report. This document draws from and updates previously published HCUP Fact Books and Statistical Briefs, which can be found at http://www.hcup-us.ahrq.gov/reports.jsp and http://www.hcup-us.ahrq.gov/reports/statbriefs.jsp.