# SOURCES AND METHODS

## Unit of Analysis

The unit of analysis is the hospital stay rather than the patient. All discharges have been weighted to produce national estimates.

## Coding Diagnoses and Procedures

The diagnoses and procedures associated with an inpatient hospitalization can be defined using several different medical condition classification systems. The following four systems are used within this report to identify specific diagnoses and procedures: International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM), Clinical Classifications Software (CCS), Diagnosis Related Groups (DRGs), and Major Diagnostic Categories (MDCs).

The most detailed system is the ICD-9-CM that contains over 12,000 detailed diagnoses and 3,500 detailed procedures. Each discharge record in the NIS is associated with one or more ICD-9-CM diagnosis code(s) and may contain one or more ICD-9-CM procedure code(s) if a procedure was performed during that hospitalization.

To make the number of ICD-9-CM diagnoses and procedures more manageable, AHRQ has designed the CCS tool that groups ICD-9-CM codes into 260 diagnostic and 231 procedure categories. This software aggregates similar diagnoses or procedures into clinically meaningful categories. More information on CCS can be found online (www.ahrq.gov/data/hcup; http://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp). CCS codes are used extensively in this report to define groups of diagnoses and procedures for analysis. The CCS codes allow the reader to quickly and easily recognize patterns and trends in broad categories of hospital utilization.

In addition, diagnoses can also be grouped into DRGs. DRGs comprise a classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedures), age, and other relevant criteria. Each hospital stay has one DRG assigned to it. The Centers for Medicare and Medicaid Services (CMS) uses this classification system as a basis for Medicare payments for inpatient hospital stays.

DRGs, in turn, can be summarized into MDCs, which are broad groups of DRGs such as Diseases and Disorders of the Nervous System or Diseases and Disorders of the Eye. Each hospital stay has one DRG and one MDC assigned to it.

## Exhibit Diagnoses and Procedures

Throughout this report, combinations of diagnostic and procedure codes are used to isolate specific conditions or procedures. These codes are defined below by exhibit number.

### SECTION 2 DIAGNOSES

#### EXHIBIT 2.1

Maternal CCS categories:

183 | Hypertension complicating pregnancy, childbirth, and the puerperium (high blood pressure during pregnancy)
184 | Early or threatened labor
185 | Prolonged pregnancy
189 | Previous C-section
190 | Fetal distress and abnormal forces of labor
191 | Polyhydramnios and other problems of amniotic cavity (excess amniotic fluid and other problems of amniotic cavity)
192 | Umbilical cord complication
193 | Trauma to external female genitals (vulva) and area between anus and vagina (perineum)
196 | Normal pregnancy and/or delivery

Other maternal CCS categories:

176 | Contraceptive and procreative management (birth control or helping with conception)
177 | Spontaneous abortion
178 | Induced abortion
179 | Postabortion complications (complications following abortion)
180 | Ectopic pregnancy (abdominal or tubal pregnancy)
181 | Other complications of pregnancy
182 | Hemorrhage during pregnancy, abruptio placenta, placenta previa (bleeding and placenta disorders during pregnancy)
186 | Diabetes or abnormal glucose tolerance complicating pregnancy, childbirth, or the puerperium (diabetes or high blood glucose during pregnancy)
187 | Malposition, malpresentation (breech birth and other disorders of baby’s position during birth)
188 | Obstructed labor or fetopelvic disproportion
194 | Forceps delivery
195 | Other maternal complications of birth, puerperium affecting management of mother (other maternal complications of birth and period after childbirth)

Infant CCS categories:

218 | Liveborn (newborn infant)
219 | Short gestation, low birth weight, and fetal growth retardation (premature birth and low birth weight)
220 | Intrauterine hypoxia and birth asphyxia (lack of oxygen to baby in uterus or during birth)
221 | Infant respiratory distress syndrome
222 | Hemolytic jaundice and perinatal jaundice (infant jaundice following birth)
223 | Birth trauma
224 | Other perinatal conditions (other conditions occurring around the time of birth)

#### EXHIBIT 2.5

Circulatory CCS categories:

99 | Hypertension with complications and secondary hypertension (high blood pressure with complications)
100 | Acute myocardial infarction (heart attack)
101 | Coronary atherosclerosis (coronary artery disease)
102 | Non-specific chest pain
106 | Cardiac dysrhythmias (irregular heart beat)
108 | Congestive heart failure, nonhypertensive
109 | Acute cerebrovascular disease (stroke)
110 | Occlusion or stenosis of precerebral arteries (blockage of arteries before brain)
112 | Transient cerebral ischemia (mini-stroke)
114 | Peripheral and visceral atherosclerosis (hardening of arteries outside heart)
118 | Phlebitis, thrombophlebitis, and thromboembolism (inflammation and blood clots in the veins)

Other circulatory CCS categories:

96 | Heart valve disorders
97 | Peri-, endo-, and myocarditis, cardiomyopathy (disorders of heart muscle and surrounding tissue, except that caused by tuberculosis or sexually transmitted disease)
98 | Essential hypertension (high blood pressure)
103 | Pulmonary heart disease (heart disease due to lung disorders)
104 | Other and ill-defined heart disease
105 | Conduction disorders (disturbance of electrical activity of heart)
107 | Cardiac arrest and ventricular fibrillation (uncoordinated contraction of heart)
111 | Other and ill-defined cerebrovascular disease (other blockage of brain blood supply)
113 | Late effects of cerebrovascular disease (late effects of stroke)
115 | Aortic, peripheral, and visceral artery aneurysms (ballooning or rupture of an artery)
116 | Aortic and peripheral arterial embolism or thrombosis (arterial blood clots)
117 | Other circulatory disease (other blood vessel disease)
119 | Varicose veins of lower extremity (varicose veins in leg)
120 | Hemorrhoids
121 | Other diseases of veins and lymphatics (lymph system)

#### EXHIBIT 2.6

Diabetes CCS categories:

49 | Diabetes mellitus without complication
50 | Diabetes mellitus with complications

#### EXHIBIT 2.7

Pressure sore ICD-9-CM codes:

707.0 | Decubitus ulcer
707.00 | Decubitus ulcer, unspecified site
707.01 | Decubitus ulcer, elbow
707.02 | Decubitus ulcer, upper back
707.03 | Decubitus ulcer, lower back
707.04 | Decubitus ulcer, hip
707.05 | Decubitus ulcer, buttock
707.06 | Decubitus ulcer, ankle
707.07 | Decubitus ulcer, heel
707.09 | Decubitus ulcer, other site

#### EXHIBIT 2.8

Alcoholism and alcohol abuse ICD-9-CM codes:

291.0 | Alcohol withdrawal delirium
291.1 | Alcohol-induced persisting amnestic disorder
291.2 | Alcohol-induced persisting dementia
291.3 | Alcohol-induced psychotic disorder with hallucinations
291.4 | Idiosyncratic alcohol intoxication
291.5 | Alcohol-induced psychotic disorder with delusions
291.8 | Other specified alcohol-induced mental disorders
291.81 | Alcohol withdrawal
291.82 | Alcohol-induced sleep disorders
291.89 | Other
291.9 | Unspecified alcohol-induced mental disorders
303.00 | Acute alcoholic intoxication, unspecified
303.01 | Acute alcoholic intoxication, continuous
303.02 | Acute alcoholic intoxication, episodic
303.03 | Acute alcoholic intoxication, in remission
303.90 | Other and unspecified alcohol dependence, unspecified
303.91 | Other and unspecified alcohol dependence, continuous
303.92 | Other and unspecified alcohol dependence, episodic
303.93 | Other and unspecified alcohol dependence, in remission
305.00 | Alcohol abuse, unspecified
305.01 | Alcohol abuse, continuous
305.02 | Alcohol abuse, episodic
305.03 | Alcohol abuse, in remission
357.5 | Alcoholic polyneuropathy
425.5 | Alcoholic cardiomyopathy
535.3 | Alcoholic gastritis
535.31 | Alcoholic gastritis, with hemorrhage
571.0 | Alcoholic fatty liver
571.1 | Acute alcoholic hepatitis
571.2 | Alcoholic cirrhosis of liver
571.3 | Alcoholic liver damage, unspecified
760.71 | Noxious influences affecting fetus or newborn via placenta or breast milk, alcohol
790.3 | Excessive blood level of alcohol
V11.3 | Personal history of mental disorder, alcoholism
V79.1 | Special screening for mental disorders and developmental handicaps, alcoholism

#### EXHIBIT 2.9

Mental health CCS categories:

650 | Adjustment disorders
652 | Attention-deficit, conduct, and disruptive behavior disorders
653 | Delirium, dementia, and amnestic and other cognitive disorders
657 | Mood disorders
659 | Schizophrenia and other psychotic disorders
660 | Substance-related disorders

Other mental health CCS categories:

651 | Anxiety disorders
654 | Developmental disorders
655 | Disorders usually diagnosed in infancy, childhood, or adolescence
656 | Impulse control disorders, not elsewhere classified
658 | Personality disorders
661 | Miscellaneous mental disorders

#### EXHIBIT 2.10

Injury CCS categories:

225 | Joint disorders and dislocations, trauma-related
226 | Fracture of neck of femur (hip fracture)
227 | Spinal cord injury
228 | Skull and face fractures
229 | Fracture of upper limb (arm)
230 | Fracture of lower limb (leg)
231 | Other fractures
232 | Sprains and strains
233 | Intracranial injury (brain injury)
234 | Crushing injury or internal injury
235 | Open wounds of head, neck, and trunk
236 | Open wounds of extremities (arms and legs)
239 | Superficial injury, contusion (bruise)
240 | Burns
241 | Poisoning by psychotropic agents (psychiatric drugs)
242 | Poisoning by other medications and drugs
243 | Poisoning by nonmedicinal substances (substances other than medicine)
244 | Other injuries and conditions due to external causes

#### EXHIBIT 2.11

Influenza CCS category:

123 | Influenza

### SECTION 3 PROCEDURES

Because the NIS is limited to inpatient hospital data, conditions treated or procedures performed in outpatient settings are not reflected here.

#### EXHIBIT 3.4

Childbirth DRG categories:

370 | Cesarean section with complications and comorbidities
371 | Cesarean section without complications and comorbidities
372 | Vaginal delivery with complicating diagnoses
373 | Vaginal delivery without complicating diagnoses
374 | Vaginal delivery with sterilization and/or dilation and curettage
375 | Vaginal delivery with operating room procedure except sterilization and/or dilation and curettage

Within DRG 370–371 and 372–375, all-listed diagnoses were also subsetted using the following CCS diagnosis category:

189 | Previous C-section

#### EXHIBIT 3.5

Cardiovascular CCS categories:

44 | CABG (coronary artery bypass graft, procedure to restore blood supply to the heart muscle)
45 | PTCA (percutaneous transluminal coronary angioplasty, procedure involving use of a balloon-tipped catheter to enlarge a narrowed artery)
51 | Endarterectomy (surgical removal of an obstructing clot from the arteries of the neck and head)

In addition, abdominal aortic aneurysm repair was defined using the following ICD-9-CM procedures and diagnoses:

Any one of the following ICD-9-CM procedures:

38.34 | Resection of aorta with anastomosis
38.44 | Resection of abdominal aorta with replacement
38.64 | Other excision of aorta
39.71 | Endovascular implantation of graft in abdominal aorta

AND

Any one of the following ICD-9-CM diagnoses:

441.3 | Abdominal aneurysm, ruptured
441.4 | Abdominal aneurysm without mention of rupture

#### EXHIBIT 3.6

Bariatric surgery procedures were identified using these steps: 1) identify likely bariatric procedures using ICD-9-CM procedure codes; 2) identify additional likely stays for bariatric surgeries using a combination of DRG and ICD-9-CM categories; 3) remove stays where the procedures were performed because of cancer; and 4) eliminate cases where an obesity diagnosis was not present.

1) Bariatric procedures using ICD-9-CM procedure codes:

44.31 | High gastric bypass
44.38 | Laparoscopic gastroenterostomy
44.39 | Other gastroenterostomy
44.68 | Laparoscopic gastroplasty
44.69 | Other
44.95 | Laparoscopic gastric restrictive procedure
44.96 | Laparoscopic revision of gastric restrictive procedure
44.97 | Laparoscopic removal of gastric restrictive device(s)
44.98 | (Laparoscopic) adjustment of size of adjustable gastric restrictive device

2) Additional likely stays for bariatric surgeries. If the DRG was equal to 288 (O.R. procedures for obesity), additional bariatric surgery procedures were defined using the following ICD-9-CM categories:

44.5 | Revision of gastric anastomosis
44.99 | Other operations on the stomach
45.91 | Small-to-small intestinal anastomosis

3) For all cases above, exclude cancer cases defined by the following ICD-9-CM diagnosis categories:

150.0–159.9 | Malignant neoplasm of digestive organs and peritoneum
230.1–230.9 | Carcinoma in situ of digestive organs

4) Exclude cases without one of the following ICD-9-CM diagnostic codes for obesity:

278.0 | Obesity
278.00 | Obesity, unspecified
278.01 | Morbid obesity
V77.8 | Obesity

#### EXHIBIT 3.7

Orthopedic procedure CCS categories:

142 | Partial excision of bone
145 | Treatment of fracture or dislocation of radius and ulna (lower arm)
146 | Treatment of fracture or dislocation of hip and femur
147 | Treatment of fracture or dislocation of lower extremity (leg, other than hip or femur)
152 | Arthroplasty of knee (surgical reconstruction or replacement of knee)
153 | Hip replacement, total and partial
157 | Amputation of lower extremity (leg, foot, or toe)
158 | Spinal fusion (correction of an unstable part of the spine by joining two or more vertebrae)

Other orthopedic procedure CCS categories:

143 | Bunionectomy (repair of toe deformities)
144 | Treatment of facial fracture or dislocation
148 | Other fracture and dislocation procedure
149 | Arthroscopy (procedure to view the inside of a joint through a lighted tube and to diagnose and treat problems)
150 | Division of joint capsule, ligament or cartilage
151 | Excision of semilunar cartilage of knee
154 | Arthroplasty other than hip or knee (surgical reconstruction or replacement of other joints)
155 | Arthrocentesis (procedure that involves introducing a needle into a joint to remove joint fluid)
156 | Injections and aspirations of muscles, tendons, bursa, joints, and soft tissue
159 | Other diagnostic procedures on musculoskeletal system
160 | Other therapeutic procedures on muscles and tendons
161 | Other operating room therapeutic procedures on bone
162 | Other operating room therapeutic procedures on joints
163 | Other non-operating room therapeutic procedures on musculoskeletal system
164 | Other operating room therapeutic procedures on musculoskeletal system