# SPECIAL TOPIC

## EXHIBIT 5.1 Uninsured Inpatient Hospital Stays: Admission Source and Discharge Status

Share of Uninsured and Insured Stays Admitted through the Emergency Department, 2005

Share of Uninsured and Insured Stays by Discharge Status, 2005

Five percent (nearly 2.1 million) of the 39.2 million U.S. community hospital discharges in 2005 were considered uninsured because they were not covered by private insurance or public programs.

Admission Source:

- A greater percentage of uninsured admissions (59 percent) than insured admissions (42 percent) originated in the emergency department.

Discharge Status:

- Hospital patients who were uninsured were 3 times more likely to leave against medical advice than insured patients.
  - Three percent of all uninsured stays, but only 1 percent of insured stays, resulted in a discharge against medical advice.
  - Twenty percent of all discharges who left the hospital against medical advice were uninsured.
- Uninsured patients were about one-third as likely as those with insurance to be referred to other health resources, such as home health care or nursing home care. Lack of referral following an uninsured stay can often be associated with lack of patient resources as well as lack of need because of the relative youth of the uninsured patient.
- Once admitted to the hospital, uninsured patients were half as likely to die in the hospital as those insured because uninsured patients tend to be younger.