# SPENDING FOR HOSPITAL INPATIENT STAYS

## EXHIBIT 4.1 Costs for the Most Frequent Diagnoses

Top 20 Inpatient Principal Diagnoses with the Highest Aggregate Costs, 1997, 2004, and 2005, Ordered by Rank for 2005

PRINCIPAL DIAGNOSIS | TOTAL INFLATION-ADJUSTED^*^ HOSPITAL COSTS IN BILLIONS | | | PERCENT OF TOTAL COSTS | | | RANK
PRINCIPAL DIAGNOSIS | 1997 | 2004 | 2005 | 1997 | 2004 | 2005 | 1997 | 2004 | 2005
All diagnoses | $209.2 | $303.5 | $310.9 | 100 | 100 | 100
Coronary atherosclerosis (coronary artery disease) | 14.0 | 16.3 | 15.5 | 7 | 5 | 5 | 1 | 1 | 1
Acute myocardial infarction (heart attack) | 8.7 | 11.6 | 10.9 | 4 | 4 | 4 | 2 | 2 | 2
Pneumonia (except that caused by tuberculosis or sexually transmitted disease) | 8.5 | 10.1 | 10.7 | 4 | 3 | 3 | 3 | 5 | 3
Congestive heart failure, nonhypertensive | 6.4 | 10.7 | 10.5 | 3 | 4 | 3 | 5 | 3 | 4
Liveborn (newborn infant) | 7.6 | 10.6 | 9.8 | 4 | 3 | 3 | 4 | 4 | 5
Osteoarthritis (degenerative joint disease) | 4.5 | 8.7 | 9.7 | 2 | 3 | 3 | 8 | 6 | 6
Complication of medical device, implant or graft | 5.3 | 8.4 | 8.9 | 3 | 3 | 3 | 6 | 7 | 7
Septicemia (blood infection) | 3.9 | 6.7 | 8.4 | 2 | 2 | 3 | 9 | 8 | 8
Spondylosis, intervertebral disc disorders, other back problems (disorders of intervertebral discs and bones on spinal column) | 3.3 | 6.5 | 7.1 | 2 | 2 | 2 | 12 | 9 | 9
Adult respiratory failure, insufficiency, or arrest | 3.2 | 5.4 | 7.0 | 2 | 2 | 2 | 15 | 12 | 10
Cardiac dysrhythmias (irregular heart beat) | 3.4 | 6.2 | 6.0 | 2 | 2 | 2 | 11 | 11 | 11
Acute cerebrovascular disease (stroke) | 5.2 | 6.2 | 5.9 | 2 | 2 | 2 | 7 | 10 | 12
Rehabilitation care, fitting of prostheses, and adjustment of devices | 3.6 | 5.1 | 5.1 | 2 | 2 | 2 | 10 | 13 | 13
Complications of surgical procedures or medical care | 2.8 | 4.6 | 4.7 | 1 | 2 | 2 | 18 | 14 | 14
Chronic obstructive pulmonary disease and bronchiectasis (chronic obstructive lung disease) | 3.2 | 3.8 | 4.2 | 2 | 1 | 1 | 14 | 17 | 15
Biliary tract disease (gall bladder disease) | 3.2 | 4.1 | 4.1 | 2 | 1 | 1 | 13 | 15 | 16
Diabetes mellitus with complications | 2.6 | 4.0 | 3.9 | 1 | 1 | 1 | 19 | 16 | 17
Fracture of neck of femur (hip fracture) | 3.0 | 3.8 | 3.9 | 1 | 1 | 1 | 16 | 18 | 18
Non-specific chest pain | 1.6 | 3.6 | 3.5 | 1 | 1 | 1 | 36 | 20 | 19
Mood disorders (depression and bipolar disorders) | 3.0 | 3.6 | 3.4 | 1 | 1 | 1 | 17 | 19 | 20
Total for top 20 conditions | 96.7 | 140.0 | 142.9 | 46 | 46 | 46

* Adjusted for inflation using the GDP deflator (http://www.bea.gov/national/nipaweb/TableView.asp#Mid, Table 1.1.4. Price Indexes for Gross Domestic Product)

The top 20 principal diagnoses with the highest aggregate inpatient hospital costs represented 46 percent of the $310.9 billion total cost for all stays in U.S. community hospitals in 2005, the same share as in 1997 and 2004.

The most costly diagnoses:

- The two most costly conditions treated in U.S. hospitals in 2005 were heart-related conditions. Six of the 20 most costly conditions were cardiac diseases and these six conditions together accounted for 17 percent of all community hospital costs.
- The three most costly inpatient diagnoses unrelated to heart disease were pneumonia, newborn infant (because of the number of discharges), and osteoarthritis.
- At least two of the top 20 most costly inpatient conditions were related to complications of medical care—complication of medical device, implant, or graft and complications of surgical procedures or medical care.
- Blood infections (septicemia), another costly condition, also may represent a complication of treatment for some patients.

Increasing costs:

- Of the top 20 costliest inpatient diagnoses, inflation-adjusted costs for adult respiratory failure or arrest showed the most dramatic increase from 2004 to 2005, growing by 29.9 percent. Respiratory failure grew at 12 times the average annual growth in inpatient costs for all diagnoses for the same time period.
- The total inflation-adjusted cost of hospitalizations for septicemia increased by 25.1 percent from 2004 to 2005, after averaging annual increases of 8.1 percent from 1997 to 2004.
- In inflation-adjusted terms, hospital stays for osteoarthritis increased in cost by 10.8 percent from 2004 to 2005, similar to an average annual increase of 10.0 percent from 1997 to 2004.
- The rate of growth in inflation-adjusted costs of hospitalizations for pneumonia doubled to 5.8 percent from 2004 to 2005, compared to an average annual increase in cost of 2.5 percent from 1997 to 2004.

Stable or decreasing costs:

- Aggregate inpatient hospital costs adjusted for inflation increased 2.4 percent between 2004 and 2005. However, costs for half of the top 20 most costly conditions (mood disorders, newborn infants, stroke, heart attack, coronary artery disease, irregular heart beat, non-specific chest pain, congestive heart failure, diabetes with complications, and rehabilitation care) did not increase.

Growth in Inflation-adjusted Hospitalization Costs for Six of the Most Costly Cardiovascular Conditions,* 1998–2005

* Includes coronary artery disease, heart attacks, congestive heart failure, irregular heart beat, stroke and non-specific chest pain.

** Adjusted for inflation using the GDP deflator (http://www.bea.gov/national/nipaweb/TableView.asp#Mid, Table 1.1.4. Price Indexes for Gross Domestic Product)

- As a matter of fact, for these cardiovascular conditions (coronary artery disease, heart attack, irregular heart beat, stroke, and non-specific chest pain), the combined inflation-adjusted costs grew at a faster rate and then slowed.
  - From 1997 to 2000, combined inflation-adjusted hospitalization costs for these most expensive cardiovascular conditions grew at progressively faster rates.
  - Growth peaked in 2000 and then gradually slowed.
  - In 2005, the combined inflation-adjusted costs for these conditions ($52 million) were not statistically different from the costs in 2001 through 2004.

## EXHIBIT 4.2 Average Charges for the Most Frequent Conditions

Hospital charges are the amounts usually seen by a patient when they receive their hospital bill. However, charges seldom represent what is actually paid for hospital stays because of negotiated discounts, but they do offer a useful benchmark for comparing the relative costliness of conditions.

- Diagnoses related to newborns and infants comprised four of the top ten diagnoses with the highest charges per hospital stay in 2005.
- The highest average charge per hospital stay is not always associated with the highest average charge per day, particularly if the type of stay is long and complicated.
  - For example, hospitalizations for infant respiratory distress syndrome had the highest mean charge per stay at $114,200, more than five times the average charge per stay for all diagnoses ($22,300) in 2005.
  - The average length of stay for infant respiratory distress syndrome was 25.7 days, more than five times the average length of stay for all diagnoses (4.7 days) in 2005.

Average Charge per Stay and per Day for the Top 10 Principal Diagnoses with Highest Charges per Stay, 2005

- Similarly, hospitalizations for premature birth and low birth weight had the lowest average per day charges ($3,400) among this high charge-per-stay group of diagnoses because the length of stay was long.
- By contrast, two diagnoses related to the cardiovascular system, heart valve disorders ($98,300 per stay) and aneurysm (ballooning or rupture of an artery) ($70,000 per stay), were among the top ten high charge-per-stay principal diagnoses with the highest charges per day in 2005. This occurred because their lengths of stay were among the shortest of the high charge-per-stay diagnoses and because their treatments involve expensive invasive procedures.
- Three cancers, leukemia (cancer of the blood), Hodgkin’s disease (cancer of the lymphatic system), and stomach cancer, were among the top ten principal diagnoses with the highest charges per stay.
- At $60,800, the charges per hospital stay for cancer of the stomach ranked tenth among those diagnoses with the highest per stay charges.