# HOSPITAL INPATIENT STAYS BY PROCEDURE

## EXHIBIT 3.1 Most Frequent All-listed Procedures

Number, Percent Distribution, and Rank of Discharges for the Most Frequent All-listed Inpatient Hospital Procedures, 1997, 2004, and 2005

ALL-LISTED PROCEDURES | NUMBER OF STAYS WITH THE PROCEDURE IN THOUSANDS | | | PERCENT OF DISCHARGES WITH THE PROCEDURE | | | RANK
ALL-LISTED PROCEDURES | 1997 | 2004 | 2005 | 1997 | 2004 | 2005 | 1997 | 2004 | 2005
All discharges | 34,679 | 38,662 | 39,164
All discharges with procedure | 21,187 | 23,835 | 24,145 | 100 | 100 | 100
Blood transfusion | 1,098 | 2,228 | 2,359 | 5 | 9 | 10 | 5 | 1 | 1
Diagnostic cardiac catheterization, coronary arteriography (diagnostic procedure to explore the functioning of the heart) | 1,461 | 1,611 | 1,589 | 7 | 7 | 7 | 1 | 2 | 2
Repair of obstetric laceration | 1,137 | 1,342 | 1,334 | 5 | 6 | 6 | 3 | 3 | 3
Cesarean section (C-section) | 800 | 1,271 | 1,304 | 4 | 5 | 5 | 9 | 4 | 4
Circumcision | 1,164 | 1,212 | 1,237 | 5 | 5 | 5 | 2 | 7 | 5
Upper gastrointestinal endoscopy (procedure to view and biopsy the esophagus, stomach, and first portion of intestine through a lighted tube) | 1,105 | 1,267 | 1,224 | 5 | 5 | 5 | 4 | 5 | 6
Respiratory intubation and mechanical ventilation | 919 | 1,240 | 1,223 | 4 | 5 | 5 | 7 | 6 | 7
Prophylactic vaccinations and inoculations | 567 | 849 | 954 | 3 | 4 | 4 | 14 | 10 | 8
Fetal monitoring | 1,002 | 1,047 | 911 | 5 | 4 | 4 | 6 | 8 | 9
Artificial rupture of membranes to assist delivery | 747 | 866 | 885 | 4 | 4 | 4 | 10 | 9 | 10

Rankings of the top 10 most frequently performed procedures were based on all-listed procedures.

- Six out of ten hospital stays had a procedure associated with them, and this proportion changed little since 1997.
- With few exceptions, there was little change in the list of the top 10 procedures performed in U.S. hospitals since 1997.
  - Blood transfusions were the most common procedure performed during a hospitalization in 2005. Six percent of all discharges (or ten percent of all discharges with a procedure) involved blood transfusions in 2005, up from 3 percent in 1997.
  - Another procedure that increased over this time period was vaccinations, which rose from 3 percent in 1997 to 4 percent in 2005.
  - Diagnostic cardiac catheterization and coronary arteriography (a procedure to explore the functioning of the heart) was the second most frequent procedure in 2004 and 2005.
- Several of the most common procedures were performed during pregnancy- and childbirth-related hospitalizations. These procedures included repair of obstetric laceration, Cesarean section (C-section), circumcision, fetal monitoring, and artificial rupture of membranes to assist delivery. Together, discharges with these procedures accounted for 23 percent of all hospitalizations with a procedure in 2005.
- Upper gastrointestinal endoscopy (a procedure to view and biopsy the upper digestive tract) was the sixth most common procedure among all hospital stays with a procedure.
- Respiratory intubation and mechanical ventilation (placing patients on a mechanical breathing machine) was also among the 10 most frequent procedures during hospitalization.

## EXHIBIT 3.2 Most Frequent All-listed Procedures by Age

Number and Percent Distribution of Discharges for the Most Frequent All-listed Inpatient Hospital Procedures by Age Group, 1997, 2004, and 2005

AGE GROUP AND ALL-LISTED PROCEDURES | NUMBER OF DISCHARGES IN THOUSANDS | | | PERCENT OF ALL DISCHARGES | | | PERCENT OF AGE-SPECIFIC DISCHARGES
AGE GROUP AND ALL-LISTED PROCEDURES | 1997 | 2004 | 2005 | 1997 | 2004 | 2005 | 1997 | 2004 | 2005
All discharges, all ages^†^ | 34,679 | 38,662 | 39,164 | 100.0 | 100.0 | 100.0
< 1 year, all discharges | 4,426 | 4,898 | 4,978 | 12.8 | 12.7 | 12.7 | 100.0 | 100.0 | 100.0
Circumcision | 1,159 | 1,206 | 1,232 | 3.3 | 3.1 | 3.1 | 26.2 | 24.6 | 24.7
Prophylactic vaccinations and inoculations | 549 | 794 | 865 | 1.6 | 2.1 | 2.2 | 12.4 | 16.2 | 17.4
Ophthalmologic and otologic diagnosis and treatment (vision and hearing diagnosis and treatment) | * | 339 | 471 | * | 0.9 | 1.2 | * | 6.9 | 9.5
Respiratory intubation and mechanical ventilation | 163 | 214 | 196 | 0.5 | 0.6 | 0.5 | 3.7 | 4.4 | 3.9
Diagnostic spinal tap | 147 | 104 | 125 | 0.4 | 0.3 | 0.3 | 3.3 | 2.1 | 2.5
1–17 years, all discharges | 1,821 | 1,784 | 2,059 | 5.3 | 4.6 | 5.3 | 100.0 | 100.0 | 100.0
Appendectomy (removal of appendix) | 74 | 87 | 95 | 0.2 | 0.2 | 0.2 | 4.1 | 4.9 | 4.6
Cancer chemotherapy | 43 | 46 | 64 | 0.1 | 0.1 | 0.2 | 2.4 | 2.6 | 3.1
Blood transfusion | 26 | 52 | 59 | 0.1 | 0.1 | 0.2 | 1.4 | 2.9 | 2.9
Repair of obstetric laceration | 58 | 53 | 54 | 0.2 | 0.1 | 0.1 | 3.2 | 3.0 | 2.6
Diagnostic spinal tap | 43 | 47 | 49 | 0.1 | 0.1 | 0.1 | 2.4 | 2.6 | 2.4
18–44 years, all discharges | 9,444 | 10,323 | 10,041 | 27.2 | 26.7 | 25.6 | 100.0 | 100.0 | 100.0
Repair of obstetric laceration | 1,079 | 1,287 | 1,278 | 3.1 | 3.3 | 3.3 | 11.4 | 12.5 | 12.7
Cesarean section (C-section) | 773 | 1,238 | 1,270 | 2.2 | 3.2 | 3.2 | 8.2 | 12.0 | 12.6
Fetal monitoring | 952 | 1,005 | 876 | 2.7 | 2.6 | 2.2 | 10.1 | 9.7 | 8.7
Artificial rupture of membranes to assist delivery | 706 | 830 | 850 | 2.0 | 2.1 | 2.2 | 7.5 | 8.0 | 8.5
Episiotomy (surgical incision into the perineum and vagina to prevent traumatic tearing during delivery) | 813 | 490 | 418 | 2.3 | 1.3 | 1.1 | 8.6 | 4.7 | 4.2
45–64 years, all discharges | 6,496 | 8,546 | 8,660 | 18.7 | 22.1 | 22.1 | 100.0 | 100.0 | 100.0
Diagnostic cardiac catheterization, coronary arteriography (diagnostic procedure to explore the functioning of the heart) | 578 | 681 | 674 | 1.7 | 1.8 | 1.7 | 8.9 | 8.0 | 7.8
Blood transfusion | 247 | 568 | 601 | 0.7 | 1.5 | 1.5 | 3.8 | 6.6 | 6.9
Upper gastrointestinal endoscopy (procedure to view and biopsy the esophagus, stomach and first portion of intestine through a lighted tube) | 275 | 369 | 356 | 0.8 | 1.0 | 0.9 | 4.2 | 4.3 | 4.1
PTCA (percutaneous transluminal coronary angioplasty, procedure involving use of a balloon-tipped catheter to enlarge a narrowed artery) | 247 | 344 | 349 | 0.7 | 0.9 | 0.9 | 3.8 | 4.0 | 4.0
Respiratory intubation and mechanical ventilation | 186 | 312 | 310 | 0.5 | 0.8 | 0.8 | 2.9 | 3.7 | 3.6
65+ years, all discharges | 12,484 | 13,059 | 13,374 | 36.0 | 33.8 | 34.2 | 100.0 | 100.0 | 100.0
Blood transfusion | 652 | 1,294 | 1,377 | 1.9 | 3.3 | 3.5 | 5.2 | 9.9 | 10.3
Diagnostic cardiac catheterization, coronary arteriography (diagnostic procedure to explore the functioning of the heart) | 773 | 805 | 789 | 2.2 | 2.1 | 2.0 | 6.2 | 6.2 | 5.9
Upper gastrointestinal endoscopy (procedure to view and biopsy the esophagus, stomach and first portion of intestine through a lighted tube) | 653 | 689 | 666 | 1.9 | 1.8 | 1.7 | 5.2 | 5.3 | 5.0
Respiratory intubation and mechanical ventilation | 431 | 516 | 524 | 1.2 | 1.3 | 1.3 | 3.5 | 4.0 | 3.9
PTCA (percutaneous transluminal coronary angioplasty, procedure involving use of a balloon-tipped catheter to enlarge a narrowed artery) | 299 | 405 | 409 | 0.9 | 1.0 | 1.0 | 2.4 | 3.1 | 3.1

* Statistics based on estimates with a relative standard error (standard error/weighted estimate) greater than 0.30 or with standard error = 0 in the nationwide statistics are not reliable.

† Includes a small number of discharges (less than 55,000 or 0.1 percent) with missing age.

The most frequent procedures usually varied by age group, except for individuals ages 45–64 and ages 65 and above: these two groups had in common the five most frequently performed procedures.

- The most common procedures performed on infants are those associated with birth.
  - Circumcision was the most common procedure for children under 1 year of age during the period 1997 to 2005. In 2005, more than 1.2 million circumcisions were performed in the hospital.
  - Vaccinations, the second most common procedure, increased by 40 percent, from 12.4 percent of all discharges for children under 1 year of age in 1997 to 17.4 percent in 2005.
- Appendectomy was the most common procedure for children ages 1–17. Other top procedures included cancer chemotherapy, blood transfusion, repair of obstetric laceration in adolescent deliveries, and diagnostic spinal tap.
- Blood transfusions were among the top 5 procedures in three age groups: 1–17 years, 45–64 years and 65 years and older. The number of hospital stays involving a transfusion more than doubled from 1997 to 2005 for each of these age groups.
- Pregnancy- and childbirth-related procedures accounted for the five most common procedures for individuals ages 18–44. Among these procedures, C-sections increased in frequency from 1997 to 2005. Episiotomy, a surgical incision to prevent traumatic tearing during vaginal delivery, decreased in frequency for this age group between 1997 and 2005.
- Heart-related procedures—diagnostic procedures to explore the functioning of the heart and PTCAs—were two of the five most common procedures for individuals ages 45–64, as well as for those 65 and above.
- Upper gastrointestinal endoscopy and respiratory intubation and mechanical ventilation were two of the five most common procedures for individuals ages 45–64 as well as for individuals 65 and above during the 1997 to 2005 period.

## EXHIBIT 3.3 Childbirth

Percent of Childbirth Stays by Birth Type, 2005

Pregnancy and childbirth is the second most common reason for admission to the hospital (see Exhibit 1.3). The types of procedures used for childbirth have changed over time.

- Vaginal births with no previous Cesarean section (C-section) accounted for the majority of the 4.2 million childbirth- related stays in 2005, at 67 percent.
- However, the number of C-sections (first time and repeat) grew significantly between 1998 and 2005. At the same time, the number of vaginal births after C-section (VBAC) fell noticeably, from 156,000 in 1998 to 62,000 in 2005.
- Overall, C-section deliveries made up 31 percent of all maternal discharges in 2005, up from the 21 percent that persisted from 1994 to 1998.

Number of Maternal Stays for C-Section and VBAC, 1993–2005

Percent of Maternal Stays with Deliveries by C-section, 1993–2005

## EXHIBIT 3.4 Cardiovascular Procedures

Number of Inpatient Hospital Cardiovascular Procedures, 1993–2005

Cardiovascular procedures to treat heart disease and stroke are the most common reasons for admission to the hospital for both men and women, excluding pregnancy and childbirth.

- The volume of percutaneous transluminal coronary angioplasty (PTCA) procedures grew rapidly, nearly doubling from 418,000 in 1993 to 800,000 in 2005.
- Prior to 1997, the number of coronary artery bypass grafts increased, but after 1997 they began to decline. In 1997, 426,000 of these procedures were performed; by 2005, the figure had dropped to 278,000.
- Two other high-volume cardiovascular procedures, endarterectomy for 1995 through 2005 and abdominal aortic aneurysm repair for 1993 through 2005, remained fairly stable.

## EXHIBIT 3.5 Bariatric Surgery

Number of Bariatric Surgery Discharges, 1995–2005

* Statistic has a relative standard error greater than .30 and is not considered reliable.

Bariatric surgery reduces the size of the stomach to achieve weight loss for people who are morbidly obese. It may be used to control the effects of serious medical conditions, such as diabetes.

- From 1995 to 2004, the total number of bariatric surgeries increased from 8,000 to 123,000—a 15-fold increase over nine years. The most rapid increase began in 1998.
- In 2005, the number of bariatric surgeries performed in an inpatient hospital setting did not continue to grow. There were several potential reasons for this stagnation in growth.
- One reason for this decline may be that more surgeries are being performed in outpatient settings. A second reason may be that insurers are responding to the rapidly increasing use of the procedures by removing bariatric surgeries from the list of covered procedures or by being more selective in approving providers.^1^
  1 Bradley DW, Sharma BK. Centers of Excellence in Bariatric Surgery: design, implementation, and one-year outcomes. Surgery for Obesity and Related Diseases. 2006 Sep-Oct;2(5):513-7; Nguyen NT, Paya M, Stevens CM, Mavandadi S, Zainabadi K, Wilson SE. The relationship between hospital volume and outcome in bariatric surgery at academic medical centers. Annals of Surgery. 2004 Oct;240(4):586-93.

## EXHIBIT 3.6 Orthopedic Procedures

Number of Discharges with Any Musculoskeletal Procedures, 1993–2005

Hospital stays for musculoskeletal treatments often involve repair of fractures and joint procedures to relieve pain.

- While the volume of musculoskeletal procedures was relatively constant between 1993 and 2000, discharges with musculoskeletal procedures rose from 2.7 million to 3.4 million (a 24- percent increase) from 2000 to 2005.
- Of the most frequently performed musculoskeletal procedures, spinal fusion grew the most rapidly—nearly 140 percent over the 12-year period.
- Arthroplasty of the knee and hip replacement were the second and third fastest growing reasons for hospitalizations related to orthopedic treatments. Arthroplasty of the knee grew 89 percent and hip replacements grew 46 percent from 1993 to 2005.

Growth in Discharges with Procedures on the Musculoskeletal System, 1993–2005

Taken together, the most frequent musculoskeletal (or orthopedic) procedures increased with age, but the distribution of specific treatments differed by age group in 2005.

For patients less than 18 years of age:

- Repair of leg or hip fractures and dislocations was the predominant orthopedic procedure for the very young.

For patients 18–44 years of age:

- Spinal fusion was the most frequent orthopedic procedure.
- Repair of leg fractures and dislocations below the thigh was the second most common orthopedic procedure for this group.

For patients 45–64 years of age:

- Arthroplasty of the knee also was the most common procedure, accounting for one in five musculoskeletal- related discharges.
- Spinal fusion was the second most common procedure, at 15 percent of orthopedic discharges in this age group.

For patients 65–84 years of age:

- Arthroplasty of the knee was the most frequent procedure, accounting for one-quarter of all orthopedic discharges.
- Hip replacement was the second most common orthopedic procedure for this age group, while hip or femur repair ranked third.

For patients 85 years of age and older:

- Hip and femur fracture repair was the most common musculoskeletal procedure for this age group, representing one in three of all orthopedic procedures.
- Hip replacements, the second most common procedure, accounted for one in five of all orthopedic procedures for these patients.

Percent Distribution* of the Most Frequent Musculoskeletal All-listed Procedures within Age Groups, 2005

* Unmarked bar segments equal one percent or less. Remaining percentages (not shown) represent miscellaneous and low frequency procedures.