# HOSPITAL INPATIENT STAYS BY DIAGNOSIS

## EXHIBIT 2.1 Most Frequent Principal Diagnoses

Number of Discharges, Percent Distribution, and Rank of Most Frequent Principal Diagnoses for Inpatient Hospital Stays, 1997, 2004, and 2005

PRINCIPAL DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | | | PERCENT OF DISCHARGES | | | RANK
PRINCIPAL DIAGNOSIS | 1997 | 2004 | 2005 | 1997 | 2004 | 2005 | 1997 | 2004 | 2005
All discharges | 34,679 | 38,662 | 39,164 | 100.0 | 100.0 | 100.0
Pregnancy, childbirth, and infants | 8,237 | 9,175 | 9,145 | 23.8 | 23.7 | 23.4 | 1 | 1 | 1
Pneumonia (except that caused by tuberculosis or sexually transmitted disease) | 1,232 | 1,213 | 1,355 | 3.6 | 3.1 | 3.5 | 3 | 2 | 2
Coronary atherosclerosis (coronary artery disease) | 1,407 | 1,192 | 1,110 | 4.1 | 3.1 | 2.8 | 2 | 3 | 3
Congestive heart failure, nonhypertensive | 991 | 1,104 | 1,090 | 2.9 | 2.9 | 2.8 | 4 | 4 | 4
Non-specific chest pain | 538 | 846 | 825 | 1.6 | 2.2 | 2.1 | 10 | 5 | 5
Osteoarthritis (degenerative joint disease) | 418 | 659 | 738 | 1.2 | 1.7 | 1.9 | 17 | 9 | 6
Mood disorders (depression and bipolar disorders) | 641 | 792 | 713 | 1.8 | 2.0 | 1.8 | 6 | 6 | 7
Cardiac dysrhythmias (irregular heart beat) | 572 | 694 | 697 | 1.7 | 1.8 | 1.8 | 8 | 8 | 8
Acute myocardial infarction (heart attack) | 732 | 695 | 662 | 2.1 | 1.8 | 1.7 | 5 | 7 | 9
Spondylosis, intervertebral disc disorders, other back problems (disorders of intervertebral discs and bones in spinal column) | 536 | 616 | 647 | 1.5 | 1.6 | 1.7 | 11 | 10 | 10
Chronic obstructive pulmonary disease and bronchiectasis (chronic obstructive lung disease) | 551 | 556 | 630 | 1.6 | 1.4 | 1.6 | 9 | 12 | 11
Complication of medical device, implant or graft | 491 | 601 | 616 | 1.4 | 1.6 | 1.6 | 12 | 11 | 12
Skin and subcutaneous tissue infections | 330 | 505 | 582 | 1.0 | 1.3 | 1.5 | 24 | 16 | 13
Fluid and electrolyte disorders (primarily dehydration or fluid overload) | 468 | 555 | 574 | 1.4 | 1.4 | 1.5 | 13 | 13 | 14
Septicemia (blood infection, except in labor) | 413 | 452 | 538 | 1.2 | 1.2 | 1.4 | 18 | 21 | 15
All maternal discharges | 4,338 | 4,763 | 4,716 | 100.0 | 100.0 | 100.0
Trauma to external female genitals (vulva) and area between anus and vagina (perineum), related to childbirth | 713 | 785 | 784 | 16.4 | 16.5 | 16.6 | 1 | 1 | 1
Previous C-section | 271 | 456 | 481 | 6.3 | 9.6 | 10.2 | 4 | 2 | 2
Normal pregnancy and/or delivery | 544 | 338 | 325 | 12.5 | 7.1 | 6.9 | 2 | 3 | 3
Early or threatened labor | 261 | 255 | 236 | 6.0 | 5.4 | 5.0 | 5 | 4 | 4
Fetal distress and abnormal forces of labor | 420 | 247 | 234 | 9.7 | 5.2 | 5.0 | 3 | 5 | 5
Prolonged pregnancy | 104 | 218 | 234 | 2.4 | 4.6 | 5.0 | 11 | 8 | 6
Hypertension complicating pregnancy, childbirth and the puerperium (high blood pressure during pregnancy) | 185 | 224 | 220 | 4.3 | 4.7 | 4.7 | 8 | 7 | 7
Umbilical cord complication | 259 | 235 | 217 | 6.0 | 4.9 | 4.6 | 6 | 6 | 8
Polyhydramnios and other problems of amniotic cavity (excess amniotic fluid and other problems of amniotic cavity) | 202 | 192 | 191 | 4.7 | 4.0 | 4.1 | 7 | 9 | 9
All infant discharges | 3,899 | 4,411 | 4,429 | 100.0 | 100.0 | 100.0
Liveborn (newborn infant) | 3,777 | 4,249 | 4,228 | 96.9 | 96.3 | 95.5 | 1 | 1 | 1
Other perinatal conditions (other conditions occurring around the time of birth) | 56 | 72 | 94 | 1.4 | 1.6 | 2.1 | 2 | 2 | 2
Hemolytic jaundice and perinatal jaundice (infant jaundice following birth) | 33 | 47 | 57 | 0.8 | 1.1 | 1.3 | 3 | 3 | 3
Short gestation, low birth weight, and fetal growth retardation (premature birth and low birth weight) | 22 | 25 | 31 | 0.6 | 0.6 | 0.7 | 4 | 4 | 4
Infant respiratory distress syndrome | 8 | 16 | 16 | 0.2 | 0.4 | 0.4 | 5 | 5 | 5
Birth trauma | 1 | 1 | 1 | 0.0 | 0.0 | 0.0 | 7 | 6 | 6
Intrauterine hypoxia and birth asphyxia (lack of oxygen to baby in uterus or during birth) | 1 | 1 | 1 | 0.0 | 0.0 | 0.0 | 6 | 7 | 7

The top 15 most frequently occurring principal diagnoses accounted for half of all discharges in 2005. While 12 of the 15 most frequent principal diagnoses in 2005 were among the most frequent diagnoses in 1997, there were notable changes within the rankings.

Among all discharges:

- Conditions related to pregnancy, childbirth, and infants were by far the most frequent reason for hospitalizations, at 23 percent of discharges in 2005, and were unchanged in rank across the years.
- Pneumonia was the second most common principal diagnosis, at 3.5 percent of discharges in 2005.
- Circulatory diseases accounted for 5 of the top 10 most frequent principal diagnoses in 2005, as they did in 1997 and 2004.
  - The volume of stays for congestive heart failure, non-specific chest pain, and irregular heart beat increased over this period.
  - However, the volume of stays for coronary artery disease (coronary atherosclerosis) and for heart attack (acute myocardial infarction) dropped noticeably between 1997 and 2005.
  - Heart attack stays dropped in rank from fifth in 1997 to ninth in 2005.
- Diagnosis of degenerative joint disease (osteoarthritis) grew by over 75 percent in volume between 1997 and 2005, and thus moved from seventeenth to sixth among the most common principal diagnoses.
- Skin and subcutaneous tissue infections moved from the twenty-fourth most frequent diagnosis in 1997 to the thirteenth in 2005. Hospitalizations for these infections grew from 330,000 to 582,000, a 76 percent increase over that time period.

Among maternal and infant discharges:

- Stays for normal pregnancy and/or delivery and for fetal distress and abnormal forces of labor both declined by more than 40 percent from 1997 to 2005, and, in turn, fell in rank.
- The volume of prolonged pregnancies doubled from 1997 through 2005 and moved up in the ranking of all causes for maternal discharges from 11th to 6th.
- High blood pressure during pregnancy, umbilical cord complication, and excess amniotic fluid and other problems of the amniotic cavity accounted for about 14 percent of principal diagnoses of all maternal discharges in 1997, 2004, and 2005.
- About 95 percent of all infant discharges in 2005 had a principal diagnosis of “newborn infant,” while conditions such as infant jaundice, premature birth and low birth weight, and respiratory distress syndrome accounted for the remaining 5 percent of these discharges.

## EXHIBIT 2.2 Most Frequent Diagnoses by Age

Number of Discharges and Percent Distribution of the Most Frequent Principal Diagnoses by Age, 1997, 2004, and 2005

AGE GROUP AND PRINCIPAL DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | | | PERCENT OF TOTAL DISCHARGES | | | PERCENT OF AGE-SPECIFIC TOTAL DISCHARGES
AGE GROUP AND PRINCIPAL DIAGNOSIS | 1997 | 2004 | 2005 | 1997 | 2004 | 2005 | 1997 | 2004 | 2005
All ages^*^ | 34,679 | 38,662 | 39,164
< 1 year | 4,426 | 4,898 | 4,978 | 12.8 | 12.7 | 12.7 | 100.0 | 100.0 | 100.0
Liveborn (newborn infant) | 3,776 | 4,244 | 4,223 | 10.9 | 11.0 | 10.8 | 85.3 | 86.7 | 84.8
Acute bronchitis | 108 | 112 | 107 | 0.3 | 0.3 | 0.3 | 2.4 | 2.3 | 2.2
Hemolytic jaundice and perinatal jaundice (infant jaundice following birth) | 33 | 47 | 56 | 0.1 | 0.1 | 0.1 | 0.7 | 1.0 | 1.1
Pneumonia (except that caused by tuberculosis or sexually transmitted disease) | 55 | 39 | 43 | 0.2 | 0.1 | 0.1 | 1.3 | 0.8 | 0.9
Short gestation, low birth weight, and fetal growth retardation (premature birth and low birth weight) | 22 | 25 | 31 | 0.1 | 0.1 | 0.1 | 0.5 | 0.5 | 0.6
1–17 years | 1,821 | 1,784 | 2,059 | 5.3 | 4.6 | 5.3 | 100.0 | 100.0 | 100.0
Pneumonia (except that caused by tuberculosis or sexually transmitted disease) | 135 | 108 | 142 | 0.4 | 0.3 | 0.4 | 7.4 | 6.0 | 6.9
Asthma | 159 | 133 | 139 | 0.5 | 0.3 | 0.4 | 8.7 | 7.4 | 6.8
Fluid and electrolyte disorders (primarily dehydration or fluid overload) | 64 | 79 | 98 | 0.2 | 0.2 | 0.3 | 3.5 | 4.4 | 4.8
Appendicitis and other appendiceal conditions | 65 | 82 | 90 | 0.2 | 0.2 | 0.2 | 3.6 | 4.6 | 4.3
Mood disorders (depression and bipolar disorders) | 64 | 84 | 73 | 0.2 | 0.2 | 0.2 | 3.5 | 4.7 | 3.6
18–44 years | 9,444 | 10,323 | 10,041 | 27.2 | 26.7 | 25.6 | 100.0 | 100.0 | 100.0
Trauma to external female genitals (vulva) and area between anus and vagina (perineum), related to childbirth | 676 | 754 | 753 | 1.9 | 2.0 | 1.9 | 7.2 | 7.3 | 7.5
Previous C-section | 270 | 453 | 478 | 0.8 | 1.2 | 1.2 | 2.9 | 4.4 | 4.8
Mood disorders (depression and bipolar disorders) | 335 | 416 | 364 | 1.0 | 1.1 | 0.9 | 3.5 | 4.0 | 3.6
Normal pregnancy and/or delivery | 511 | 323 | 312 | 1.5 | 0.8 | 0.8 | 5.4 | 3.1 | 3.1
Fetal distress and abnormal forces of labor | 399 | 238 | 224 | 1.2 | 0.6 | 0.6 | 4.2 | 2.3 | 2.2
45–64 years | 6,496 | 8,546 | 8,660 | 18.7 | 22.1 | 22.1 | 100.0 | 100.0 | 100.0
Coronary atherosclerosis (coronary artery disease) | 526 | 492 | 461 | 1.5 | 1.3 | 1.2 | 8.1 | 5.8 | 5.3
Non-specific chest pain | 242 | 396 | 388 | 0.7 | 1.0 | 1.0 | 3.7 | 4.6 | 4.5
Osteoarthritis (degenerative joint disease) | 105 | 235 | 272 | 0.3 | 0.6 | 0.7 | 1.6 | 2.7 | 3.1
Pneumonia (except that caused by tuberculosis or sexually transmitted disease) | 199 | 246 | 271 | 0.6 | 0.6 | 0.7 | 3.1 | 2.9 | 3.1
Spondylosis, intervertebral disc disorders, other back problems (disorders of intervertebral discs and bones in spinal column) | 190 | 249 | 266 | 0.5 | 0.6 | 0.7 | 2.9 | 2.9 | 3.1
65+ years | 12,482 | 13,059 | 13,374 | 36.0 | 33.8 | 34.2 | 100.0 | 100.0 | 100.0
Congestive heart failure, nonhypertensive | 783 | 820 | 815 | 2.3 | 2.1 | 2.1 | 6.3 | 6.3 | 6.1
Pneumonia (except that caused by tuberculosis or sexually transmitted disease) | 711 | 713 | 781 | 2.0 | 1.8 | 2.0 | 5.7 | 5.5 | 5.8
Coronary atherosclerosis (coronary artery disease) | 810 | 641 | 596 | 2.3 | 1.7 | 1.5 | 6.5 | 4.9 | 4.5
Cardiac dysrhythmias (irregular heart beat) | 402 | 477 | 469 | 1.2 | 1.2 | 1.2 | 3.2 | 3.7 | 3.5
Osteoarthritis (degenerative joint disease) | 300 | 405 | 419 | 0.9 | 1.0 | 1.1 | 2.4 | 2.9 | 3.1

* Includes a small number of discharges (less than 55,000 or 0.1 percent) with missing age.

The principal diagnoses for hospitalizations generally varied by age. Older patients were more frequently admitted with cardiovascular and musculoskeletal conditions and younger patients were more frequently admitted with pregnancy- and childbirth-related conditions.

- Pneumonia was a top five condition for four out of the five age groups in 2005—children under 1 year of age, children ages 1–17, adults ages 45–64, and adults 65 and above.
- Asthma was the second most common reason for hospital admission among children ages 1–17.
- Mood disorders (depression and bipolar disorders) were the fifth and third most common diagnoses among children ages 1–17 and adults ages 18–44, respectively. For the 18–44 age group, this was the only non-childbirth diagnosis to rank among the top five diagnoses.
- Cardiovascular conditions were the most common diagnoses for adults ages 45 and above. However, specific diagnoses differed somewhat between age groups for older adults:
  - Coronary atherosclerosis (coronary artery disease) and non-specific chest pain were the most frequent cardiac conditions for adults ages 45–64.
  - Congestive heart failure, coronary atherosclerosis, and irregular heart beat were the most common cardiac conditions for adults 65 years and older.
- For patients ages 45 and older, the number of discharges with a principal diagnosis of coronary atherosclerosis dropped over time, but remained among the top 3 reasons for hospitalization.
  - For individuals ages 45–64, hospital stays for coronary atherosclerosis dropped by 12 percent—from 526,000 in 1997 to 461,000 in 2005.
  - For those 65 years and older, hospital stays for coronary atherosclerosis declined by 26 percent—from 810,000 in 1997 to 596,000 in 2005.
- Among 45–64 year olds, discharges with a principal diagnosis of non-specific chest pain rose by 60 percent from 1997 to 2005.
- Among individuals 65 and older, hospital stays for congestive heart failure exhibited very little change between 1997 and 2005.
- Among individuals 65 and older, hospital stays for irregular heart beat rose 19 percent between 1997 and 2004, but stabilized between 2004 and 2005.

## EXHIBIT 2.3 Most Frequent Diagnoses by Gender

Number of Discharges,^*^ Percent Distribution, and Rank of Most Frequent Principal Diagnoses for Inpatient Hospital Stays by Gender, 2005

PRINCIPAL DIAGNOSIS | MALES | | | FEMALES
PRINCIPAL DIAGNOSIS | NUMBER OF DISCHARGES IN THOUSANDS | PERCENT OF MALE DISCHARGES | RANK | NUMBER OF DISCHARGES IN THOUSANDS | PERCENT OF FEMALE DISCHARGES | RANK
All diagnoses | 16,053 | 100.0 | | 22,980 | 100.0
Pregnancy and childbirth | – | – | – | 4,705 | 20.5 | 1
Liveborn (newborn infant) | 2,160 | 13.5 | 1 | 2,058 | 9.0 | 2
Coronary atherosclerosis (coronary artery disease) | 691 | 4.3 | 2 | 418 | 1.8 | 7
Pneumonia (except that caused by tuberculosis or sexually transmitted disease) | 645 | 4.0 | 3 | 708 | 3.1 | 3
Congestive heart failure, nonhypertensive | 524 | 3.3 | 4 | 566 | 2.5 | 4
Acute myocardial infarction (heart attack) | 392 | 2.4 | 5 | 270 | 1.2 | 20
Non-specific chest pain | 365 | 2.3 | 6 | 459 | 2.0 | 5
Cardiac dysrhythmias (irregular heart beat) | 341 | 2.1 | 7 | 355 | 1.5 | 10
Complication of medical device, implant or graft | 316 | 2.0 | 8 | 298 | 1.3 | 15
Skin and subcutaneous tissue infections | 307 | 1.9 | 9 | 273 | 1.2 | 19
Spondylosis, intervertebral disc disorders, other back problems (disorders of intervertebral discs and bones in spinal column) | 304 | 1.9 | 10 | 339 | 1.5 | 13
Mood disorders (depression and bipolar disorders) | 296 | 1.8 | 11 | 414 | 1.8 | 8
Osteoarthritis (degenerative joint disease) | 280 | 1.7 | 12 | 455 | 2.0 | 6
Urinary tract infections | 151 | 0.9 | 27 | 377 | 1.6 | 9

* Excludes a small number of discharges (less than 135,000 or 0.3 percent) with missing gender.

Most diagnoses are common to both males and females if those related to childbirth are excluded. However, some diagnoses were more frequent in one gender, in part because of differences between males and females in health-seeking behaviors and attitudes.

- Females accounted for 6 out of every 10 hospital stays—23.0 million stays in 2005. About 20 percent of all female hospitalizations were related to pregnancy and childbirth.
- Males accounted for 16.1 million hospitalizations in 2005.
- Four heart-related diagnoses—coronary atherosclerosis, congestive heart failure, non-specific chest pain, and cardiac dysrhythmias—were among the ten most common principal diagnoses for both male and female hospitalizations.
- Heart attacks (acute myocardial infarctions) ranked as the fifth most common diagnosis among males, but only the twentieth most common among females. Males accounted for 59 percent of all discharges with heart attack as the principal diagnosis.
- Complications of medical device, skin and subcutaneous tissue infections, and back problems were common diagnoses among both males and females.
  - Though these conditions were three of the ten most frequent diagnoses for men, these diagnoses were outranked by other diagnoses for women—namely, mood disorders (depression and bipolar disorders), degenerative joint disease (osteoarthritis), and urinary tract infections—which were all less common among males.

## EXHIBIT 2.4 Average Length of Stay and Average Charges

In general, longer lengths of stay are associated with higher average charges. While full charges are seldom paid because of negotiated discounts, they can be used as a benchmark for comparing the costliness of different types of hospital stays.

- The two conditions with the longest hospital stays for all patients regardless of age were related to infants—infant respiratory distress syndrome and premature birth and low birth weight.
  - These diagnoses averaged stays of 26 days, which is 11 days longer than for the next longest stay diagnosis—leukemia.
  - Infant respiratory distress syndrome also had the highest average charge for all conditions. The average charge for premature birth and low birth weight ranked sixth in 2005.
- Conditions treated with expensive technology or requiring intensive care—including spinal cord injuries, heart valve disorders, cardiac and circulatory disorders, and leukemia—had mean charges significantly higher than expected based on their average length of stay (represented by the solid line in the graph).
- Even though long lengths of stay can be costly, 3 of the 14 conditions with the longest lengths of stay had average charges that were lower than the average for all diagnoses in 2005. These were all mental health conditions—impulse control disorders, schizophrenia, and pre-adult mental disorders—that typically do not require expensive procedures as part of the hospitalization.

Inpatient Hospital Stays for Principal Diagnosis: Average Length of Stay and Average Charges, 2005

## EXHIBIT 2.5 Circulatory Conditions

Although the share of all discharges for circulatory disease was essentially equal between male (51 percent) and female (49 percent) in 2005, the gender share differed according to conditions.

- Males made up the majority of discharges with a diagnosis of coronary atherosclerosis (62 percent of the diagnosis-specific discharges), acute myocardial infarction (59 percent), and stenosis of precerebral arteries (57 percent).
- Females accounted for a larger share of discharges for transient cerebral ischemia (60 percent of diagnosis-specific discharges), non-specific chest pain (56 percent), phlebitis, thrombophlebitis, and thromboembolism (55 percent), stroke (55 percent), high blood pressure (54 percent), peripheral atherosclerosis (54 percent), and congestive heart failure (52 percent).
- Discharges with a diagnosis of irregular heart beat (cardiac dysrhythmias) were as likely to be for males as for females.

Number of Discharges, Percent Distribution, and Rank for the Most Frequent Principal Diagnoses of Circulatory Conditions by Gender, 2005

PRINCIPAL DIAGNOSIS | TOTAL^*^ | MALE | | FEMALE
PRINCIPAL DIAGNOSIS | DISCHARGES IN THOUSANDS | PERCENT MALE | RANK FOR MALES | PERCENT FEMALE | RANK FOR FEMALES
All circulatory disease discharges | 6,627 | 51 | | 49
Coronary atherosclerosis (coronary artery disease) | 1,110 | 62 | 1 | 38 | 3
Congestive heart failure, nonhypertensive | 1,090 | 48 | 2 | 52 | 1
Acute myocardial infarction (heart attack) | 662 | 59 | 3 | 41 | 6
Non-specific chest pain | 825 | 44 | 4 | 56 | 2
Cardiac dysrhythmias (irregular heart beat) | 697 | 49 | 5 | 51 | 4
Acute cerebrovascular disease (stroke) | 526 | 46 | 6 | 54 | 5
Hypertension with complications and secondary hypertension (high blood pressure with complications) | 215 | 46 | 7 | 54 | 7
Peripheral and visceral atherosclerosis (hardening of arteries other than heart) | 183 | 46 | 8 | 54 | 9
Occlusion or stenosis of precerebral arteries (blockage of arteries before brain) | 141 | 57 | 9 | 43 | 13
Transient cerebral ischemia (mini-stroke) | 183 | 40 | 10 | 60 | 8
Phlebitis, thrombophlebitis, and thromboembolism (inflammation and blood clots in the veins) | 161 | 45 | 11 | 55 | 10

* Includes a small number of discharges (less than 5,500 or 0.1 percent) with missing gender.

- In 2005, 473 out of every 100,000 men experienced a hospitalization for coronary artery disease. This was the most prevalent reason among men for a hospitalization for a circulatory condition.
- Men were more likely to be hospitalized for:
  - coronary artery disease
  - heart attack
  - occlusion of precerebral arteries
- For women, 376 out every 100,000 women were hospitalized for congestive heart failure. This was the most prevalent reason among women for a hospitalization for a circulatory condition.
- Women were more likely to be hospitalized for:
  - congestive heart failure
  - non-specific chest pain
  - stroke and mini-stroke
  - high blood pressure
  - peripheral atherosclerosis
  - phlebitis

Discharges per 100,000 Population for the Most Frequent Principal Diagnoses of Circulatory Conditions by Gender, 2005

## EXHIBIT 2.6 Diabetes

Diabetes is a chronic condition characterized by high levels of blood glucose that can lead to serious complications, including lower limb amputations and premature death. There were 2,200 diabetes-related hospitalizations per 100,000 people in the U.S. The prevalence of diabetes discharges, however, varied across age, region, and income.

- About 17 percent of all hospitalizations in 2005 involved a diagnosis of diabetes.
  - Among individuals 65 and older, there were three times as many hospital stays with a diagnosis of diabetes compared with those ages 45–64. These older patients had almost five times the number of discharges per 100,000 population as the national average.
- In the West region, there were only 1,585 hospital stays for diabetes per 100,000 population compared to more than 2,300 per 100,000 population in each of the other three regions.
- Individuals residing in the lowest median income communities were more likely to be hospitalized for diabetes. There were nearly 80 percent more diabetes admissions per 100,000 population for residents of the lowest income communities compared with the highest income communities.

Discharge Prevalence for All-listed Diabetes by Patient Age, 2005

Discharge Prevalence for All-listed Diabetes by Region, 2005

Discharge Prevalence for All-listed Diabetes by Median Income of Patients’ Zip Code,* 2005

* Quartile populations from 2005 Claritas ZIP-Demographic Data were adjusted to reflect total population estimate from the U.S. Census Bureau.

## EXHIBIT 2.7 Pressure Sores

Number of Discharges for Pressure Sores, 1993–2005

Pressure sores typically result from prolonged periods of uninterrupted pressure on the skin, soft tissue, muscle, and bone. This often occurs in wheelchair- or bedridden-patients whose positions are not changed regularly. The presence of pressure sores for patients in the hospital increases their lengths of stay and total costs.

- In 2005, 496,500 hospital stays involved a diagnosis of pressure sores.
- The number of hospital stays during which pressure sores were noted (i.e., all-listed diagnoses) increased by 76 percent from 1993 to 2005.
- The number of hospital stays for which pressure sores were the principal diagnosis changed only slightly during the period—a 17 percent increase from 1993 to 2005, or 1.3 percent annually.

## EXHIBIT 2.8 Alcoholism

Number of Discharges with a Principal Diagnosis of Alcoholism by Age, 2005

Distribution of Discharges with a Principal Diagnosis of Alcoholism by Gender and Age, 2005

Alcohol abuse and dependence can result in illness, disability, and early death. About 14 million Americans abuse or have a dependency on alcohol. More than half of American adults have a close family member who has suffered from alcoholism.^1^

1 U.S. Department of Health and Human Services. National Institute on Alcohol Abuse and Alcoholism. Alcohol Research & Health: Highlights from the Tenth Special Report to Congress—Health Risks and Benefits of Alcohol Consumption (Volume 24, Number 1). Washington, D.C.: U.S. Government Printing Office, 2000. Retrieved April 27, 2006, at http://pubs.niaaa.nih.gov/publications/arh24-1/05-11.pdf.

- In 2005, there were 298,000 discharges with a principal diagnosis of alcoholism.
- For children younger than 18 years of age, there was little gender difference in the percent of hospitalizations that involved alcoholism in 2005. This youngest age group accounted for less than one percent of all discharges with a principal diagnosis of alcoholism.
- Among adults, however, males accounted for most of the discharges in which alcoholism was the principal diagnosis in 2005.
  - Three out of four admissions for an alcohol-related principal diagnosis in the 18–44, 45–64, and 65–84 age groups were for men.
  - Although the proportion of alcohol-related stays attributable to males was lower for adults age 85 and older as compared to younger adults, the predominance of male hospitalizations for alcoholism within this oldest age group remained pronounced: Males accounted for more than two out of three hospital stays for alcohol abuse among the oldest patients.

Distribution of Discharges with a Principal Diagnosis of Alcoholism by Expected Payer, 2005

- The expected primary payer for alcohol-related stays was different than the expected payer for the typical hospital stay.
  - Private insurance was the expected payer for 30 percent of discharges with a principal diagnosis of alcoholism, the highest share for any major payer. Nevertheless, this was lower than for all conditions (35 percent).
  - Although Medicaid paid for 20 percent of all stays, it was the expected payer for 26 percent of these alcohol-related stays. Medicaid was the second most common payer for alcohol-related stays.
  - Medicare was less likely to be the expected payer for alcoholism-related stays than for other conditions. This may be attributable, in part, to older, alcohol-dependent patients often having other complications, such as circulatory disease and diabetes, which may be listed as the principal reason for admission. In addition, Medicare patients are also more likely to be female and females tend to have a lower rate of alcoholism hospitalizations.
- Uninsured patients accounted for 21 percent of alcohol-related stays, but only 5 percent of hospitalizations in general.

## EXHIBIT 2.9 Mental Health

The data for this report exclude discharges from mental health and substance abuse facilities. Nevertheless, mood disorders were the seventh most frequent reason for hospital admission in 2005 (see Exhibit 2.1). Mood disorders represented only one of many mental health conditions for which people were hospitalized in that year. These conditions generally differed with age.

- In 2005, there were 1.8 million community hospital stays with a principal diagnosis of mental illness or substance abuse.

Youth less than 18 years of age:

- Mood disorders (depression and bipolar disorders) accounted for 58 percent of mental disorders for which this age group was hospitalized.
- Attention deficit disorder (ADD), conduct, and disruptive behavior disorders accounted for 13 percent of all mental health discharges for this age group.

Patients 18–44 years of age:

- Mood disorders were the most common mental disorder for which adults ages 18–44 were admitted to the hospital, though mood disorders constituted a smaller share (43 percent) of admissions in this age group than among younger patients.
- The other common mental health conditions for this age group were substance-related disorders (26 percent) and schizophrenia and other psychotic disorders (23 percent), which were much more common in this age group than among youth.

Distribution* of Discharges by Age for Stays with a Principal Diagnosis of a Mental Health Condition, 2005

* Unmarked bar segments equal two percent or loss.

Patients 45–64 years of age:

- Mood disorders were also the most common mental disorder for this age group, representing 39 percent of all mental health stays for patients ages 45–64.
- Substance-related disorders (29 percent) were the second most common mental health condition for this group, while schizophrenia and other psychotic disorders (25 percent) were third.

Patients ages 65–84 years and ages 85 years and older:

- Delirium, dementia, amnestic, and other cognitive disorders were the most frequent mental health conditions for inpatients ages 65–84 (38 percent) and ages 85 years and older (69 percent).
- Mood disorders were the second most common mental health reason for admission for these age groups: this condition accounted for 30 percent of mental health discharges for patients 65–84 years old and 15 percent for patients ages 85 years and older.

## EXHIBIT 2.10 Injuries

Number of Stays, Average Cost per Stay, Average Length of Stay, and In-hospital Death Rate for Discharges with an Injury Diagnosis, 2005

PRINCIPAL DIAGNOSIS | TOTAL NUMBER OF STAYS IN THOUSANDS | AVERAGE COSTS PER STAY | AVERAGE LENGTH OF STAY IN DAYS | IN-HOSPITAL DEATH RATE (PERCENT)
All injuries | 1,891 | $10,300 | 4.6 | 3.1
Spinal cord injury | 12 | 38,800 | 12.7 | 5.9
Crushing injury or internal injury | 106 | 16,900 | 6.7 | 3.4
Intracranial injury (brain injury) | 171 | 16,500 | 6.4 | 9.1
Burns | 41 | 15,300 | 7.1 | 2.4
Fracture of neck of femur (hip fracture) | 317 | 12,300 | 6.3 | 2.8
Fracture of lower limb (leg) | 267 | 10,600 | 4.6 | 0.5
Other fractures | 194 | 10,100 | 5.3 | 1.4
Skull and face fractures | 53 | 9,600 | 3.4 | 0.4
Joint disorders and dislocations, trauma-related | 33 | 9,100 | 3.1 | 0.3
Fracture of upper limb (arm) | 154 | 8,000 | 3.2 | 0.4
Open wounds of extremities (arms and legs) | 50 | 7,100 | 3.5 | 0.2
Other injuries and conditions due to external causes | 102 | 7,000 | 3.5 | 3.3
Open wounds of head, neck, and trunk | 38 | 6,900 | 2.6 | 0.6
Poisoning by nonmedicinal substances (substances other than medicine) | 25 | 6,700 | 3.1 | 1.7
Poisoning by other medications and drugs | 155 | 5,500 | 2.9 | 1.2
Sprains and strains | 45 | 5,400 | 2.6 | 0.2
Superficial injury, contusion (bruise) | 53 | 4,900 | 3.4 | 0.6
Poisoning by psychotropic agents (psychiatric drugs) | 77 | 4,800 | 2.5 | 0.8

Growth in Number of Discharges with a Principal Diagnosis of Injuries, 1997–2005

In 2005, nearly 5 percent of all hospital stays—about 1.9 million hospitalizations—were for treatment of an injury. Costs, lengths of stay, and hospital death rates differed according to the type of injury.

- The most common injury-related reason for hospitalization was hip fracture (317,000 stays), followed by leg fracture (267,000 stays), other fractures (194,000 stays), brain injury (171,000 stays) and poisoning by nonpsychiatric drugs (155,000 stays).
- The highest in-hospital death rates were for brain injury (9.1 percent) and spinal cord injury (5.9 percent).
- Spinal cord injury was the most expensive type of injury, with an average hospital cost per stay of $38,800 and a mean length of stay of 12.7 days. However, these hospitalizations accounted for less than 1 percent of all injury-related hospital stays.

Over time, the number of hospitalizations associated with each injury has changed.

- Admissions for poisoning by nonpsychiatric medications and drugs rose by 32 percent from 1997 to 2005, perhaps reflecting in part the increased use of pharmaceuticals.
- Hospitalizations for burns increased 18 percent from 1997 to 2005, as did poisonings by psychiatric drugs.
- Admissions for joint disorders and dislocations due to trauma, as well as sprains and strains, dropped by 39 and 40 percent, respectively, from 1997 to 2005, probably reflecting more outpatient treatment.

## EXHIBIT 2.11 Influenza

Characteristics of All Hospital Stays and Stays with a Principal Diagnosis of Influenza, 2005

CHARACTERISTICS | ALL HOSPITAL STAYS | HOSPITAL STAYS FOR INFLUENZA
Total number of discharges in thousands | 39,164 | 50
Mean length of stay in days | 4.6 | 4.1
Mean cost of hospitalization | $7,900 | $5,400
Mean hospital cost per day | $1,700 | $1,300
Aggregate costs for U.S. in millions | $310,916.2 | $272.0
Percent of admissions through the emergency department | 43% | 68%
Percent died in hospital | 2.1% | 1.6%
Percent <1 year (excluding newborns^*^) | 2% | 11%
Percent 1–64 years | 53% | 38%
Percent 65 years and above | 34% | 51%

* Newborns account for 11 percent of all hospital discharges.

Number of Discharges with a Diagnosis of Influenza, 1993–2005

Influenza (flu) is a contagious respiratory viral disease. In 2005, there were over 50,000 hospital stays principally for influenza, resulting in about $272 million in aggregate costs.

- Hospital stays for influenza in 2005, compared to all hospitalizations, were slightly shorter (4.1 versus 4.6 days) and somewhat less costly ($5,400 versus $7,900).
- Hospital admissions for influenza originated more often from the emergency department (68 percent of the time) than other conditions (43 percent of the time).
- The percent of patients admitted for influenza who died in the hospital was lower (1.6 percent) than the in-hospital death rate for all patients admitted (2.1 percent).
- Hospitalizations for influenza vary widely by year, whether counted by principal diagnosis or all-listed diagnoses. The variation by year is related to outbreaks of strains of influenza which occur in cycles.^2^ Like 1999 and 2003, 2005 was a peak year for influenza hospitalization.
  2 Centers for Disease Control and Prevention. Influenza (Flu): Clinical Description and Diagnosis. August 23, 2006. http://www.cdc.gov/flu/professionals/diagnosis/
- The elderly, young children, and individuals with certain health conditions are especially vulnerable to more severe symptoms of influenza and are more likely to require hospitalization.