# OVERVIEW STATISTICS FOR HOSPITALS AND INPATIENT HOSPITAL STAYS

## EXHIBIT 1.1 Number and Characteristics of U.S. Hospitals

Number of U.S. Registered Hospitals and Characteristics of Community Hospitals, 1997, 2004, and 2005

Hospital Categories and Characteristics | 1997 | 2004 | 2005
Number of U.S. registered hospitals^†^ | 6,100 | 5,759 | 5,756
Number of U.S. community hospitals | 5,060 | 4,919 | 4,936
Number of non-government not-for-profit hospitals | 3,000 | 2,967 | 2,958
Number of investor-owned (for-profit) community hospitals | 797 | 865 | 868
Number of State and local government community hospitals | 1,260 | 1,117 | 1,110
Community hospitals as a share of registered hospitals | 83% | 85% | 86%
Community hospitals^‡^
Discharges:
Total discharges in millions | 34.7 | 38.7 | 39.2
Discharges per 1,000 population^*^ | 127.8 | 131.7 | 132.1
Total days of care in millions | 168.1 | 179.1 | 181.5
Average length of stay in days | 4.8 | 4.6 | 4.6
Percent of discharges from:
Metropolitan hospitals | 84% | 87% | 87%
Teaching hospitals | 47% | 45% | 42%
Hospital ownership:
Non-Federal government hospitals | 14% | 14% | 14%
Private not-for-profit hospitals | 73% | 73% | 72%
Private for-profit hospitals | 13% | 13% | 13%
Population in millions^††^ | 271.4 | 293.7 | 296.4

† Statistics from the American Hospital Association’s Annual Survey of Hospitals.

‡ Statistics from the Healthcare Cost and Utilization Project (HCUP).

* Calculated using population from the U.S. Bureau of the Census.

†† Statistics from the U.S. Bureau of the Census (http://www.census.gov/popest/national/asrh/2005_nat_res.html).

Hospital costs rose rapidly and most hospital characteristics changed slowly over time.

- Of the 5,756 registered hospitals in the U.S. in 2005, 86 percent were community hospitals, a proportion that has changed little over time.
  - However, the actual number of community hospitals declined from 5,060 in 1997 to 4,936 in 2005.
  - Despite the decline in the number of community hospitals, discharges from those hospitals grew from 34.7 million in 1997 to 39.2 million in 2005, an average annual increase of 1.5 percent per year.
- The percent of community hospital discharges has changed little in terms of location, teaching status, and type of ownership.

Charges and Costs for Community Hospital Stays, 1997, 2004, and 2005

Hospital Categories and Characteristics | 1997 | 2004 | 2005
Charges and costs^*^
Average charges per stay | $11,300 | $20,400 | $22,300
Costs
Total aggregate costs in billions | $177.1 | $294.6 | $310.9
Average costs per stay | $5,100 | $7,600 | $7,900
Inflation-adjusted costs in 2005 dollars^**^
Total aggregate costs in billions | $209.2 | $303.5 | $310.9
Average costs per stay | $6,000 | $7,900 | $7,900

* Charges represent amounts billed by hospitals. These amounts are seldom paid in full by insurers. Costs are calculated from charges using reported cost-to-charge ratios calculated from information on Medicare Cost Reports, reported by hospitals to the Centers for Medicare and Medicaid Services (CMS).

** Adjusted for inflation using the GDP deflator (http://www.bea.gov/national/nipaweb/TableView.asp#Mid, Table 1.1.4. Price Indexes for Gross Domestic Product).

- The average charge on the typical bill from a U.S. community hospital rose from $11,300 in 1997 to $22,300 in 2005, an increase of 8.9 percent per year in actual dollars. Few patients or insurers paid those amounts because of discounts negotiated by insurers with hospitals.
- The aggregate cost for stays in community hospitals rose significantly between 1997 and 2005, from $177.1 billion to $310.9 billion, reflecting an average annual increase of 7.3 percent. On a per-stay basis, cost increases averaged 5.7 percent annually, resulting in an average cost per stay of $7,900 in 2005.
- After adjusting for inflation, the total cost for hospital stays nationwide rose 5.1 percent per year over the 8 years.
  - Of this increase, population growth accounted for 1.1 percentage points, increases in the number of admissions per population accounted for 0.4 percentage point (a possible effect of the gradual aging of the population), and the remainder—3.5 percentage points—was attributable, in part, to costs associated with increased service intensity from the expanded use of new technology.

## EXHIBIT 1.2 Inpatient Hospital Stays and Average Length of Stay

Number of Inpatient Stays and Average Length of Stay, 1993–2005

The average length of stay in U.S. community hospitals has stabilized since 2000, while the number of hospital stays continued to rise.

- The average length of stay (ALOS) in 2005 was 4.6 days— almost 20 percent shorter than in 1993, when the ALOS was 5.7 days. The ALOS declined throughout most of the 1990s and has stabilized in the current decade.
- The number of discharges has increased over the past 12 years, from 34.3 million discharges in 1993 to 39.2 million in 2005.
- From 1993 to 1998, the number of discharges grew very slowly, increasing by only 0.6 million.
  - Growth in the number of discharges (an average of 0.3 percent annually) did not keep pace with the growth in population (1.2 percent annually).
  - It is likely that the rapid growth in managed care plans slowed growth in hospital utilization.
- From 1998 through 2005, the number of discharges rose by 4.3 million.
  - Growth in the number of discharges (an average of 1.7 percent annually) exceeded population growth (1.1 percent annually).
  - From 1998 to 2001, low unemployment and the need for employers to attract and retain workers through generous health benefits produced a loosening of care management by insurance plans.^1^
    1 Forrest S, Goetghebeur M, Hay J. Forces Influencing Inpatient Hospital Costs in the United States. Available at http://www.bcbs.com/betterknowledge/cost/underlying-drivers.html.
  - Since 2001, growth in the number of discharges has slowed to rates that are only slightly faster than population growth (1.1 to 1.3 percent annually).

## EXHIBIT 1.3 Reasons for Hospital Stays

Percent Distribution of Discharges by Major Reason* for Hospital Stay, 2005

* Based on principal diagnosis

Circulatory conditions were the most frequent causes of hospital stays.

- Circulatory conditions accounted for 16 percent of all hospital stays in 2005. These stays were for diagnoses such as coronary atherosclerosis (coronary artery disease), congestive heart failure, heart attack, and irregular heart beat.
- Pregnancy and childbirth (12 percent) and newborns (11 percent) ranked second and third among reasons for hospitalizations. Stays related to giving birth or being born accounted for 23 percent of discharges—nearly one in four hospital stays.
- Together with respiratory conditions (10 percent of all discharges) and digestive conditions (9 percent of all discharges), the top five conditions accounted for 58 percent of all discharges.

Circulatory conditions represented a higher percentage of stays for males (20 percent) than females (13 percent).

- Males accounted for 16.1 million stays in 2005, or 41 percent of all hospitalizations.
  - Of these stays, 20 percent were for circulatory conditions, 14 percent were for newborns, 12 percent were for respiratory conditions, and 9 percent involved conditions of the digestive system.
  - These four conditions together amounted to 55 percent of all hospitalizations for males in 2005.
- Females accounted for 23.0 million stays, or 59 percent of all hospital stays in 2005.
  - Twenty percent of the stays for females were related to pregnancy and childbirth and 9 percent were for female newborns.
  - Compared to the stays for males, stays for circulatory conditions (13 percent of all stays) were a smaller percentage of all female stays.
  - Other major reasons for female hospitalizations included respiratory conditions (9 percent) and digestive system conditions (8 percent).
  - These five conditions together accounted for almost 60 percent of all female hospitalizations in 2005.

Hospital Stays for Males and Females by Major Reason,* 2005

* Based on principal diagnosis

## EXHIBIT 1.4 Admission Source

Distribution of Hospital Inpatient Stays by Admission Source, 2005

* Includes court and law enforcement admissions.

Admission source in HCUP indicates routine admission and other specific settings from which the patient might enter the hospital.

- About half (51 percent) of all admissions to hospitals in 2005 were routine admissions referred by health professionals.
- Emergency departments accounted for the second largest source of admissions (43 percent).
- Two other settings accounted for a small proportion of admissions: Other short-term hospitals (3 percent) and long-term care facilities (1 percent).
- The remainder of admissions came from court/law enforcement sources or other unknown sources.

## EXHIBIT 1.5 Discharge Status

Distribution of Hospital Inpatient Stays by Discharge Status, 2005

Discharge status indicates where the patient went after discharge from the hospital or the circumstance surrounding the discharge.

- The most common patient discharge status was routine (74 percent in 2005), with the patient being sent home without closely supervised health care.
- Discharge to a long-term care facility was the second most common type of discharge, accounting for 12 percent of discharges.
- Discharge to the home with home health care supervision accounted for 9 percent of discharges.
- Remaining discharge circumstances (to another short-term hospital, in-hospital death, or when the patient leaves against medical advice) each accounted for 2 percent or less of discharges.

## EXHIBIT 1.6 Patient Age

Distribution of U.S. Population and Hospital Discharges by Age, 2005

Older people account for a large share of hospitalizations.

- While those aged 65 and over represented 12 percent of the population in 2005, they comprised 34 percent of the hospitalizations.
- The younger patient age groups had a lower proportion of hospitalizations relative to their representation in the population.
  - Patients 18–64 years of age, at 63 percent of the population, accounted for 48 percent of hospitalizations.
  - Those under age 18, at 25 percent of the population, accounted for 18 percent of hospitalizations.

Discharges per 1,000 Population by Age Group, 2005

Discharges for an age group divided by the number of people in that age group (discharges per 1,000 population) shows that increased age is often associated with a greater chance of hospitalization.

- While there were only 42 hospital stays for every 1,000 children ages 1 to 4 in 2005, there were 574 stays for every 1,000 adults ages 85 and over.
- The one exception to the pattern of increasing hospitalizations with increasing age was for neonates less than 1 year of age. This group experienced 1,212 hospitalizations per 1,000 neonates, because nearly all births occur in the hospital and some infants require additional hospitalization in the first year of life.

## EXHIBIT 1.7 Expected Primary Payer

Percent Distribution of Discharges by Expected Primary Payer, 2005

* Includes other payers such as Workers’ Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.

** Includes discharges classified as self-pay or no charge.

The expected primary payer bears the major financial responsibility for the hospital stay. However, other payers, including the patients themselves, may also bear part of the cost of hospitalization.

- Medicare and Medicaid together assumed primary financial responsibility for over half of all hospital stays in 2005.
  - Medicare was the expected primary payer for 37 percent of all inpatient hospital discharges (14.6 million hospital stays). Medicare patients are 65 and older or disabled.
  - Medicaid was the expected primary payer for 1 out of every 5 hospital stays (7.6 million discharges) in 2005. These may include stays for patients covered by the State Children’s Health Insurance Program (SCHIP), depending on the state in which the hospital was located.
- Private insurance was the expected primary payer for 35 percent of all discharges (13.7 million hospital stays). These stays were primarily for employed persons and their families who receive health insurance coverage through their employers.
- Approximately 5 percent of all stays (2.1 million discharges) were listed as uninsured.
- Other payers accounted for 3 percent of all stays in 2005.