# HIGHLIGHTS

HCUP Facts and Figures: Statistics on Hospital-based Care in the United States in 2005 presents information derived from the 2005 HCUP Nationwide Inpatient Sample (NIS) with trend information as far back as 1993. This report includes information from the most recent database containing discharge records for all patients treated in a sample of approximately 1,000 hospitals in 2005. These discharges are weighted to represent all inpatient stays in community hospitals across the nation. Community hospitals include all non-federal, short-term acute care hospitals and exclude psychiatric and substance abuse facilities.

## Overall hospital statistics

- From 1997 to 2005, the number of community hospitals declined from 5,060 hospitals to 4,936 hospitals. Despite this decline, the volume of hospital stays grew by 4.5 million. Hospitals were able to accommodate this increase in discharges primarily because of a 4 percent reduction in the average length of stay.
- The average cost per hospital inpatient stay in 2005 was $7,900, up an average of 5.7 percent annually since 1997.
- After adjusting for inflation, the aggregate costs for all stays in community hospitals increased at a 5.1-percent average annual rate from 1997 to 2005. Population growth accounted for 1.1 percentage points of this growth, increases in the number of admissions per capita accounted for 0.4 percentage point, and 3.5 percentage points were attributable in part to increased service intensity resulting from new technology.
- Medicare and Medicaid together assumed primary financial responsibility for over half (57 percent) of all hospital stays in 2005. Medicaid paid for 1 out of 5 hospital stays.
- Six out of ten hospital stays had procedures associated with them, a proportion that has changed little since 1997.

## Childbirth and newborns

- Among the most frequent reasons for hospitalizations were childbirth and newborns, which together accounted for nearly 1 out of 4 (23 percent) of all hospitalizations in 2005.
- C-section deliveries comprised 31 percent of all maternal discharges in 2005, up from a 21-percent rate that persisted from 1994 to 1998. The number of C-sections (first time and repeat) grew significantly (67 percent) between 1996 and 2005. The number of vaginal births after C-section fell 61 percent over the same period.
- The number of stays for prolonged pregnancy more than doubled from 104,000 in 1997 to 234,000 in 2005.
- In general, longer lengths of stay were associated with higher average charges. The two conditions with the longest hospital stays for all patients regardless of age were related to infants (infant respiratory distress syndrome; premature birth and low birth weight), with average stays 11 days longer than for the next longest stay diagnosis. Infant respiratory distress syndrome was also the condition with the highest average charge per stay ($114,200) overall.

## Children

- For 1–17 year olds, hospitalizations with a principal diagnosis of asthma remained statistically unchanged (159,000 in 1997 and 139,000 in 2005).
- Mood disorders (depression and bipolar disorders) were the fifth most common reason for stays in acute care hospitals among children and adolescents.

## Young adults and middle age

- Childbirth-related conditions were the most common reasons for hospitalizations among 18–44 year olds; however, mood disorders ranked third, accounting for 364,000 hospital stays in 2005—virtually unchanged since 1997.
- Cardiovascular conditions were the most common reasons for hospitalization among 45–64 year olds.

## Elderly

- While people ages 65 and over represented 12 percent of the population in 2005, they comprised 34 percent of the hospitalizations.
- In 2005, there were 574 hospitalizations for every 1,000 adults ages 85 and older.

## Specific diagnoses and procedures

- The number of hospital stays during which pressure sores were noted continued to increase in 2005. During the 12 year period since 1993, there was a 76 percent increase in pressure sore hospitalizations.
- Three out of four admissions for alcohol-related conditions in the 18–84 age group were for men. Uninsured patients accounted for 21 percent of all alcohol-related hospital stays, although only 5 percent of all stays were uninsured.
- Hospital stays for influenza varied widely by year. 1999, 2003 and 2005 were peak years for influenza hospitalizations.
- Of the top 20 costliest inpatient diagnoses, those for adult respiratory failure and/or arrest showed the most dramatic increase in inflation-adjusted cost from 2004 to 2005, growing at 12 times the rate for all diagnoses.
- The number of hospital stays for septicemia, or sepsis, increased 30 percent from 1997 to 2005. The inflation-adjusted cost of hospitalizations for septicemia increased at twice the rate for all diagnoses over this period.
- Conditions treated with expensive technology or requiring intensive care—including spinal cord injuries, heart valve disorders, and leukemia—had mean charges significantly higher than expected based on their average length of stay.
- Aggregate inpatient hospital costs adjusted for inflation increased 2.4 percent between 2004 and 2005. However, costs for half of the top 20 most costly conditions (mood disorders, newborn infants, stroke, heart attack, coronary artery disease, irregular heart beat, non-specific chest pain, congestive heart failure, diabetes with complications, and rehabilitation care) did not increase.
- Blood transfusions were the most common procedure performed during a hospitalization in 2005, occurring in 6 percent of all discharges.

## Cardiovascular conditions and procedures

- Circulatory conditions accounted for 16 percent of all hospital stays in 2005. These stays were for diagnoses that included coronary artery disease, congestive heart failure, heart attack, and irregular heart beat.
- Six of the 20 most costly conditions associated with hospitalization were related to the heart. These six conditions (coronary artery disease, heart attack, congestive heart failure, irregular heart beat, stroke, and non-specific chest pain) together accounted for 17 percent of all community hospital costs in 2005.
- From 1997 to 2000, combined inflation-adjusted hospitalization costs for the most expensive cardiovascular conditions (coronary artery disease, heart attack, congestive heart failure, irregular heart beat, stroke, and non-specific chest pain) grew at progressively faster rates. Growth peaked in 2000 and then gradually slowed. In 2005, the combined inflation-adjusted costs for these conditions ($52 billion) were not statistically different from the costs in 2001 through 2004.
- The number of hospitalizations for congestive heart failure, non-specific chest pain, and irregular heart beat increased by 24 percent from 1997 to 2005. However, the volume of discharges with diagnoses of coronary artery disease and heart attack dropped by 17 percent over this period.
- Discharges for circulatory disease overall were essentially equally split between males and females, but differed for specific conditions. Four heart-related diagnoses—coronary artery disease, congestive heart failure, non-specific chest pain, and irregular heart beat—were among the ten most common principal diagnoses for both males and females. Heart attacks ranked as the fifth most common diagnosis among males, but only the twentieth most common among females.
- Diagnostic cardiac catheterization and arteriography (procedure to explore the functioning of the heart) was the second most frequently performed procedure overall for 2005.
- From 1993 to 2005, the volume of percutaneous transluminal coronary angioplasties (PTCA) nearly doubled. From 1993 to 1997, the number of coronary artery bypass grafts (CABG) increased, but from 1997 to 2005 the number of procedures fell by a third.
- Heart-related procedures—diagnostic cardiac catheterization and arteriography, PTCAs, and echocardiograms—were performed 50 percent more often on males than females.
- Two heart-related procedures—PTCA and cardiac catheterization and arteriography—were among the five most common procedures for individuals ages 45 and above.

## Bariatric surgery

- From 1995 to 2004, the total number of bariatric surgeries increased 15-fold. These surgeries escalated rapidly beginning in 1998.
- However, in 2005, the number of bariatric surgeries performed did not continue to grow, after increasing from 8,000 in 1995 to 123,000 in 2004. An increase in surgeries performed in out-patient settings, increased insurer selectivity of approved providers, and removal of this procedure from insurance coverage were among the potential reasons for this change in trend.

## Injuries

- Discharges with a diagnosis of poisoning by nonpsychiatric medications and drugs rose by 32 percent from 1997 through 2005, reflecting in part the increased use of pharmaceuticals.
- Hip fractures were the most common injury-related reason for hospitalization. They accounted for 317,000 hospital stays, involved a mean length of stay of 6.3 days, and resulted in an average hospital cost per stay of $12,300.

## Musculoskeletal conditions and orthopedic procedures

- While the number of stays with any orthopedic procedure remained relatively constant between 1993 and 2000, the number of stays rose by 24 percent from 2000 to 2005.
- Of the most frequently performed orthopedic procedures, spinal fusion grew the most rapidly—nearly 140 percent over the 12-year period from 1993 to 2005. Arthroplasty of the knee and hip replacement were the second and third fastest growing reasons for hospitalizations related to orthopedic treatments, respectively. Knee arthroplasties grew 89 percent, and hip replacements grew 46 percent during this period.

## Diabetes

- Diabetes-related hospitalizations occurred at a higher rate in lower income communities. There were almost 80 percent more diabetes admissions per 100,000 population among people residing in the lowest income communities (with incomes of $1–36,999) than in the highest income communities (with incomes of $61,000 and above).