# HCUP AND ITS DATA PARTNERS

HCUP is a family of powerful health care databases, software tools, and products for advancing research. Sponsored by the Agency for Healthcare Research and Quality (AHRQ), HCUP includes the largest all-payer encounter-level collection of longitudinal hospital inpatient, ambulatory surgery, and emergency department data in the United States. The HCUP Federal-State-Industry Partnership brings together the data collection efforts of many organizations—State data organizations, hospital associations, private data organizations, and the Federal government— to create this national information resource. The HCUP Partnership has grown from 8 states in 1988 to 38 in 2007.

HCUP would not be possible without the current contributions of the following data collection Partners from across the United States:

- Arizona Department of Health Services
- Arkansas Department of Health & Human Services
- California Office of Statewide Health Planning & Development
- Colorado Health & Hospital Association
- Connecticut Integrated Health Information (Chime, Inc.)
- Florida Agency for Health Care Administration
- Georgia GHA: An Association of Hospitals & Health Systems
- Hawaii Health Information Corporation
- Illinois Health Care Cost Containment Council and Department of Public Health
- Indiana Hospital&Health Association
- Iowa Hospital Association
- Kansas Hospital Association
- Kentucky Department for Public Health
- Maryland Health Services Cost Review Commission
- Massachusetts Division of Health Care Finance and Policy
- Michigan Health & Hospital Association
- Minnesota Hospital Association
- Missouri Hospital Industry Data Institute
- Nebraska Hospital Association
- Nevada Division of Health Care Financing and Policy, Department of Human Resources
- New Hampshire Department of Health & Human Services
- New Jersey Department of Health & Senior Services
- New York State Department of Health
- North Carolina Department of Health and Human Services
- Ohio Hospital Association
- Oklahoma State Department of Health
- Oregon Association of Hospitals and Health Systems
- Rhode Island Department of Health
- South Carolina State Budget & Control Board
- South Dakota Association of Healthcare Organizations
- Tennessee Hospital Association
- Texas Department of State Health Services
- Utah Department of Health
- Vermont Association of Hospitals and Health Systems
- Virginia Health Information
- Washington State Department of Health
- West Virginia Health Care Authority
- Wisconsin Department of Health & Family Services