# DEFINITIONS

For definitions of medical terms, refer to: http://www.nlm.nih.gov/medlineplus/mplusdictionary.html

Admission source: Admission source indicates where the patient was located prior to admission to the hospital.
  - Routine admission: Patient was admitted to the hospital from home, via physician or clinic referral, or due to birth (i.e., newborns). It does not include patients who were admitted from the emergency department or any other health care facility.
  - Emergency department admission: Patient was admitted to the hospital through the emergency department.
  - Long-term health care facility admission: Patient was admitted to the hospital from a long-term health care facility.
  - Other hospital admission: Patient was admitted to the hospital from another hospital.
  - Other admissions: Patient was admitted through court/law enforcement or other admission sources.
Adjusted for inflation: Cost can be adjusted for economy-wide inflation by removing increases that reflect the effect of changing average prices for all goods and services. In this report, the U.S. Bureau of Economic Analysis Gross Domestic Product Price Index is used to remove economy-wide inflation. Additional inflation that is specific to the hospital sector is not removed in this calculation. Data in Exhibit 1.1 and 4.1 are adjusted for economy-wide inflation.
Aggregate costs: Aggregate costs are the sum of all costs for all hospital stays.
Charges: Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. The charge is generally more than the amount paid to the hospital by payers for the hospitalization and is also generally more than the hospital’s costs of care.
Community hospitals: HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals (and HCUP data) include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude hospitals whose main focus is long-term care, psychiatric, and alcoholism and chemical dependency treatment, although discharges from these types of units that are part of community hospitals are included.
Costs: Costs are derived from total hospital charges using cost-to-charge ratios based on hospital accounting reports from the Centers for Medicare and Medicaid Services (CMS). Costs will tend to reflect the actual costs to produce hospital services, while charges represent what the hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used to transform charges into costs. Cost-to-charge ratios for 2005 will not be available until later this year. These ratios were estimated by multiplying the 2004 ratio for each hospital by .96, which represents the average annual change exhibited in the charge-to-cost ratios over the past few years.
Diagnoses: - Principal diagnosis: The condition established after study to be chiefly responsible for the patient’s admission to the hospital.
  - All-listed diagnoses: The principal diagnosis plus secondary conditions.
Discharge: Discharge refers to the hospital stay. The unit of analysis for HCUP data is the hospital discharge, not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate discharge from the hospital.
Discharge status: Discharge status indicates the disposition of the patient at the time of discharge from the hospital, and includes the following six categories: routine (to home), transfer to another short-term hospital, other transfers (including skilled nursing facility, intermediate care, rehabilitation care, swing bed, and another type of facility such as a nursing home), home health care, against medical advice (AMA), or died in the hospital.
Discharge per population: Discharge per population is the hospital discharge rate of a particular procedure, diagnosis, or event per 100,000 individuals. This measure indicates the prevalence of hospitalizations, procedures or diagnoses within the population.
In-hospital deaths: In-hospital deaths refer to hospitalizations in which the patient died during his or her hospital stay.
Infant discharges: Infant discharges are hospital stays during which a child is born.
Length of stay: Length of stay is the number of nights the patient remained in the hospital for his or her stay. A patient admitted and discharged on the same day has a length of stay equal to 0.
Maternal discharges: Maternal discharges are hospital stays for females who are pregnant or gave birth.
Median income: Median income is the median household income of the patient’s ZIP Code of residence. This is a proxy measure of a patient’s socioeconomic status.
Morbid obesity: Morbid obesity is defined as at least twice a person’s ideal weight, 100 pounds overweight, or a body mass index (BMI) that is greater than 39.
Neonates: Neonates are newborns and infants 30 days of age or less.
Ownership/control: Ownership/control was obtained from the American Hospital Association (AHA) Annual Survey of Hospitals and includes categories for government non-Federal (public), private not-for-profit (voluntary), and private investor-owned (proprietary). These types of hospitals tend to have different missions and different responses to government regulations and policies.
Patient age: Patient age in years, calculated based on the patient’s date of birth and admission date to the hospital.
Payers: Payer is the expected payer for the hospital stay. To make coding uniform across all HCUP data sources, Payer combines detailed categories into more general groups:
  - Medicare includes fee-for-service and managed care Medicare patients.
  - Medicaid includes fee-for-service and managed care Medicaid patients. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most state data do not identify SCHIP patients specifically, it is not possible to present this information separately.
  - Private insurance includes Blue Cross, commercial carriers, and private HMOs and PPOs.
  - Other includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.
  - Uninsured includes an insurance status of “self-pay” and “no charge.”
  When more than one payer is listed for a hospital discharge, the first-listed payer is used.
Procedures: - Principal procedure is the procedure that was performed for definitive treatment rather than one performed for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication). If two procedures appear to meet this definition, the procedure most related to the principal diagnosis is selected as the principal procedure.
  - All-listed procedures include all procedures performed during the hospital stay.
Region: Region is one of the four regions defined by the U.S. Bureau of the Census: Northeast, Midwest, South, and West.
  - Northeast is defined as Connecticut, Maine, Massachusetts, New Hampshire, New Jersey, New York, Pennsylvania, Rhode Island, and Vermont.
  - Midwest is defined as Illinois, Indiana, Iowa, Kansas, Minnesota, Missouri, Michigan, Nebraska, North Dakota, Ohio, South Dakota, and Wisconsin.
  - South is defined as Alabama, Arkansas, Delaware, District of Columbia, Florida, Georgia, Kentucky, Maryland, Mississippi, Louisiana, Tennessee, North Carolina, Oklahoma, South Carolina, Texas, Virginia, and West Virginia.
  - West is defined as Alaska, Arizona, California, Colorado, Hawaii, Idaho, Montana, Nevada, New Mexico, Oregon, Utah, Washington, and Wyoming.
  Not all states participate in HCUP, so not all states will be present in HCUP data. However, the statistics have been weighted to represent the entire U.S.
Stays: The unit of analysis for HCUP data is the hospital stay (i.e., the hospital discharge), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.