# ACKNOWLEDGMENTS

Thanks to Eva Witt and Nils Nordstrand at Thomson Healthcare for their programming support; Laurel Holmquist and Anne Pfuntner at Thomson Healthcare for their assistance in the preparation of tables and text; Gail Eisen, also at Thomson Healthcare, for her editorial assistance; Roxanne Andrews, Pamela Owens, and Claudia Steiner of AHRQ for contributions to early content decisions; and The Madison Design Group for their assistance in design and layout of the report. Special thanks to Chaya Merrill of Thomson Healthcare and Megan Hambrick of AHRQ for their helpful comments on drafts. This document draws from and updates previously published HCUP Fact Books and Statistical Briefs, which can be found at http://www.hcup-us.ahrq.gov/reports.jsp and http://www.hcup-us.ahrq.gov/reports/statbriefs.jsp.