# Results

## Key Question 1 What are the U.S. Food and Drug Administration (FDA)-regulated skin substitutes that fall under each of the following pathways: PMA, 510(k), PHS 361 [21 CFR 1270 & 1271]?

Definitions
a. PMA: Premarket approval by FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices. Class III devices support or sustain human life, are of substantial importance in preventing impairment of human health, or present a potential, unreasonable risk of illness or injury.
b. 510(k): A 510(k) is a premarketing submission made to FDA to demonstrate that the device to be marketed is as safe and effective, that is, substantially equivalent, to a legally marketed device that is not subject to PMA.
c. PHS 361 [21 CFR 1270 & 1271]: Human cells, tissues, and cellular and tissue-based products. Creates a unified registration and listing system for establishments that manufacture HCT/Ps and establishes donor eligibility, current good tissue practice, and other procedures to prevent the introduction, transmission, and spread of communicable diseases by HCT/Ps.

This section of the report addresses which skin substitute products are currently regulated by FDA for use within the United States. We note that FDA does not refer to any product or class of products as “skin substitutes,” and we are not proposing an official classification system. Key Question 1 does not address clinical effectiveness or efficacy. Our searches identified a number of products that are intended as skin substitutes but may also be used for other medical purposes. Based on FDA regulations that govern each product we identified and the origin and composition of the products, skin substitutes can be organized into four groups: human-derived products regulated as HCT/Ps (see Table 6), human- and human/animal-derived products regulated through PMA or HDE (see Table 7), animal-derived products regulated under the 510(k) process (see Table 8), and synthetic products regulated under the 510(k) process (see Table 9). In total our searches identified 57 skin substitute products.

Table 6 Human-derived products regulated solely under 21 CFR 1271 (HCT/Ps)

Product | Manufacturer | Description
AlloDerm Regenerative Tissue Matrix | LifeCell, KCI | Acellular human dermis product
Allopatch HD | Musculoskeletal Transplant Foundation | Acellular human dermis product
Alloskin | AlloSource | Allograft derived from epidermal and dermal cadaveric tissue
Cymetra Micronized AlloDerm | LifeCell, KCI | Injectable form of AlloDerm Regenerative Tissue Matrix
DermaCell and Arthroflex | LifeNet Health | Acellular human dermis product
Flex HD | Ethicon and Musculoskeletal Transplant Foundation | Acellular hydrated dermis derived from donated human allograft skin
GammaGraft | Promethean LifeSciences, Inc. | Irradiated cadaveric human skin allograft
GraftJacket | LifeCell, licensed to Wright Medical Technology and to KCI | Processed human dermal matrix
Matrix HD | RTI Biologics | Acellular human dermis product
Memoderm | Memometal Inc. | Acellular human dermis product
Puros Dermis | Zimmer Dental | A natural biological matrix
Repliform | LifeCell and Boston Scientific | Acellular human dermis product
Theraskin | Soluble Systems | Biologically active cryopreserved human skin allograft with both epidermis and dermis layers

Table 7 Human- and human/animal-derived products regulated through the premarket approval (PMA) or humanitarian device exemption (HDE) process

Product and Manufacturer | Product Description | Approval Date | FDA Product Code | FDA Intended Use/Indication for Use
Apligraf/Graftskin – Organogenesis135 | Living cell based bilayered skin substitute derived from bovine type 1 collagen and human fibroblasts and keratinocytes derived from neonatal foreskins. | 1998 PMA original 2000 PMA added diabetic ulcers | MGR (dressing, wound and burn, interactive) | “For use with standard therapeutic compression for the [underlined: treatment] of non-infected partial and full-thickness skin ulcers due to venous insufficiency of greater than 1 month duration and which have not adequately responded to conventional ulcer therapy. Apligraf is also indicated for use with standard diabetic foot ulcer care for the treatment of full-thickness neuropathic diabetic foot ulcers of greater than three weeks' duration which have not adequately responded to conventional ulcer therapy and which extend through the dermis but without tendon, muscle, capsule or bone exposure. Apligraf is contraindicated for use on clinically infected wounds. Apligraf is contraindicated in patients with known allergies to bovine collagen. Apligraf is contraindicated in patients with a known hypersensitivity to the components of the Apligraf agarose shipping medium.”
Dermagraft - Advanced Biohealing, Inc. and Smith & Nephew137 | Cryopreserved human fibroblast-derived dermal substitute on a bioabsorbable polyglactin mesh scaffold. The fibroblasts are obtained from human newborn foreskin tissue. | 2001 PMA | MGR (dressing, wound and burn, interactive) | “For use in the [underlined: treatment] of full-thickness diabetic foot ulcers greater than six weeks' duration which extend through the dermis, but without tendon muscle, joint capsule or bone exposure. Dermagraft(r) should be used in conjunction with standard wound care regimens and in patients that have adequate blood supply to the involved foot. Dermagraft is contraindicated for use in ulcers that have signs of clinical infection or in ulcers with sinus tracts. Dermagraft is contraindicated in patients with known hypersensitivity to bovine products, as it may contain trace amounts of bovine proteins from the manufacturing medium and storage solution.”

MGR is one of the FDA product codes designated for Class III device

Table 8 Animal-derived products regulated under the 510(k) process

Product and Manufacturer | Description | Clearance Date | FDA Product Code | FDA Intended Use/Indication for Use
ACell UBM Hydrated Wound Dressing – ACell, Incorporated11 | A wound dressing primarily composed of porcine collagen. | 2002 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.” The device is intended for one-time use.”
ACell UBM Lyophilized Wound Dressing – ACell, Incorporated12 | A wound dressing primarily composed of porcine collagen. | 2002 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds. The device is intended for one-time use.”
Aongen™ Collagen Matrix – Aeon Astron Europe B.V.13 | A biodegradable material composed of collagen. | 2009 | KGN (dressing, wound, collagen) | “For the management of wounds including: surgical wounds, trauma wounds, draining wounds, second degree burns, partial and full-thickness wounds, pressure ulcers, venous ulcers, vascular ulcers, diabetic ulcers, and oral wounds and sores.”
Atlas Wound Matrix – Wright Medical Technology, Inc.14 | A sterile, decellularized fenestrated or nonfenestrated processed porcine collagen dermal material. | 2009 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), draining wounds. The Atlas Wound Matrix is a collagen wound dressing that provides an environment that supports wound healing.”
Avagen Wound Dressing – Integra LifeSciences Corp.15 | A wound dressing comprised of a porous matrix of cross-linked bovine tendon collagen and glycosaminoglycan. The biodegradable matrix provides a scaffold for cellular invasion and capillary growth. | 2002 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds. The device is intended for one-time use.”
Collagen Sponge – Innocoll Pharmaceuticals16 | A collagen matrix sponge | 2010 | KGN (dressing, wound, collagen) | “For the management of wounds such as: pressure ulcers, venous stasis ulcers, diabetic ulcers, first and second degree burns, partial and full thickness wounds, and superficial injuries.”
Collagen Wound Dressing – Oasis Research, LLC17 | A wound care dressing composed of hydrolyzed bovine collagen. | 2000 | KGN (dressing, wound, collagen) | “For the management of wounds including full thickness and partial thickness wounds, pressure ulcers, venous ulcers, ulcers caused by mixed vascular etiologies, diabetic ulcers, second-degree burns, donor sites and other bleeding surface wounds, abrasions, traumatic wounds healing by secondary intention, dehisced surgical incisions.”
Collaguard™ – Innocoll Pharmaceuticals18 | A clear collagen matrix film | 2006 | KGN (dressing, wound, collagen) | “For the management of wounds such as: pressure ulcers, venous stasis ulcers, diabetic ulcers, first and second degree burns, partial and full thickness wounds, and superficial injuries.”
CollaSorb™ Collagen Wound Dressing – Hartmann-Conco Inc.19 | A wound care product composed of native collagen and calcium-alginate. | 2009 | KGN (dressing, wound, collagen) | “For the management of full and partial thickness wounds including: pressure ulcers, diabetic ulcers, ulcers caused by mixed vascular etiologies, venous ulcers, second degree burns, donor and graft sites, abrasions, dehisced surgical wounds, and traumatic wounds healing by secondary intention.”
CollaWound™ dressing – Collamatrix Inc.20 | A sterile, single use, disposable wound dressing device comprised of insoluble fibrous collagen derived from porcine. | 2006 | KGN (dressing, wound, collagen) | “For the management of partial and full thickness wounds, pressure ulcers, venous ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds, first and second degree burns, surgical wounds and superficial injuries.”
Collexa – Innocoll Pharmaceuticals21 | A collagen matrix sponge | 2010 | KGN (dressing, wound, collagen) | “For the management of wounds such as: diabetic ulcers, venous ulcers, pressure ulcers, ulcers caused by mixed vascular etiologies, full-thickness and partial-thickness wounds, abrasions, traumatic wounds, first and second degree burns, dehisced surgical wounds, and exuding wounds.”
Collieva^®^ – Innocoll Pharmaceuticals22 | A clear collagen matrix film | 2008 | KGN (dressing, wound, collagen) | “For the management of wounds such as: pressure ulcers, venous stasis ulcers, diabetic ulcers, first and second degree burns, partial and full thickness wounds, and superficial injuries.”
Coreleader Colla-Pad – Coreleader Biotech Co., Ltd.23 | A porous matrix consisting of cross-linked bovine collagen. | 2011 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, skin tears) and draining wounds.”
Dermadapt™ Wound Dressing – Pegasus Biologics, Inc.24 | A collagen-based wound dressing described as a decellularized, equine pericardial implant. | 2006 | KGN (dressing, wound, collagen) | “For the local management of moderately to heavy exuding wounds, including: partial and full thickness wounds, draining wounds, pressure sores/ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds (e.g., abrasions, lacerations, partial thickness burns, skin tears), and surgical wounds (e.g., donor sites/grafts, post-laser surgery, post-Mohs surgery, podiatric wounds, dehisced surgical incisions).”
DressSkin – TEI Biosciences Inc.25 | A wound dressing composed of hydrolyzed bovine collagen. | 2003 | KGN (dressing, wound, collagen) | “For the management of wounds that include: partial and full thickness wounds; pressure, diabetic, and venous ulcers; second-degree burns; surgical wounds—donor sites/grafts, post Mohs surgery, post-laser surgery, podiatric, wound dehiscence; trauma wounds—abrasions, lacerations, and skin tears; tunneled/undermined wounds; draining wounds.”
E-Z Derm - AM Scientifics, Ltd26 | Biosynthetic wound dressing made from porcine tissue. | 1994 | KGN (dressing, wound, collagen) | No FDA summary available online
EndoForm Dermal Template–Mesynthes27 | Extracellular matrix derived from ovine forestomach. | 2010 | KGN (dressing, wound, collagen) | “For single use in the [underlined: treatment] of the following wounds: partial and full-thickness wounds; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled/undermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, second-degree burns, and skin tears); draining wounds.”
Excellagen – Tissue Repair Company28 | A wound care device composed of formulated, 2.6% (26 mg/mL) fibrillar bovine dermal collagen (Type I).923 | 2011 | KGN (dressing, wound, collagen) | “For the management of wounds including partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds.”
FortaDerm™ Wound Dressing – Organogenesis, Inc.29 | A single-layer fenestrated sheet of porcine intestinal collagen. | 2001 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post laser surgery, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds.”
HA Absorbent Wound Dressing – ConvaTec, A Division of E.R. Squibb and Sons, Inc.30 | An absorbent fibrous fleece (F) or rope (R), entirely composed of HYAFF 11p75™, a benzyl ester of hyaluronic acid. | 1999 | KGN (dressing, wound, collagen) | “For over-the-counter use, HA Absorbent Wound Dressing-F may be used for wounds such as: abrasions, lacerations, minor cuts and first degree burns. Under the supervision of a healthcare professional, HA Absorbent Wound Dressing-F may be used for wounds such as: leg ulcers, pressure ulcers (stages I-IV), and diabetic ulcers, surgical wounds (post-operative, donor sites, dermatological), second degree burns; management of wounds that are prone to bleeding such as wounds that have been mechanically or surgically débrided, donor sites, and traumatic wounds. HA Absorbent Wound Dressing-R is indicated for use in the management of deep exuding wounds, sinuses, and fistulae.”
Helicoll – ENCOLL Corp.31 | A translucent, off-white, semi-occlusive, self-adhering and ready to use pre-sterilized Type-1 Collagen Sheet. | 2004 | KGN (dressing, wound, collagen) | “For the topical wound management that includes: partial and full-thickness wounds, pressure ulcers, venous ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds (abrasions, lacerations, second-degree burns, skin tears), and surgical wounds (donor sites/grafts, post-Mohs' surgery, post-laser surgery, podiatric), wound dehiscence.”
Integra/Bilayer Matrix Wound Dressing - Integra Lifesciences Corp.32 | Bilayered matrix composed of a porous layer of cross-linked bovine tendon collagen and glycosaminoglycan and a semipermeable polysiloxane (silicone) layer. | 2002 | FRO (dressing, wound, drug) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic and vascular ulcers, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds.”
Integra™ Flowable Wound Matrix33 | A wound care device comprised of granulated cross-linked bovine tendon collagen and glycosaminoglycan. | 2007 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, skin tears) and draining wounds.”
LTM Wound Dressing – LifeCell Corp.34 | A terminally sterilized sheet of the processed porcine dermal matrix | 2008 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post laser surgery, podiatric wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns and skin tears), draining wounds, and other bleeding surface wounds.”
MatriStem - ACell, Inc.35 | Extracellular matrix product derived from porcine urinary bladder tissue. | 2009 | KGN (dressing, wound, collagen) | “For the management of wounds that including: partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, skin tears) and draining wounds.”
MatriStem^®^ Wound Matrix – ACell, Inc.36 | A sterile, porcine-derived, naturally-occurring lyophilized extracellular matrix sheet. | 2011 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunnel/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
Matrix Collagen Wound Dressing – Collagen Matrix, Inc.37 | An opaque, absorbent, collagen membrane matrix intended for topical use. | 2004 | KGN (dressing, wound, collagen) | “For the management of moderately to heavily exudating wounds and to control minor bleeding. Collagen Topical Wound Dressing may be used for the management of exudating wounds such as: pressure ulcers, venous stasis ulcers, diabetic ulcers, acute wounds (for example trauma and surgical wounds), and partial thickness burns.”
Medline Collagen Wound Dressing – Medline Industries, Inc.38 | Not available in 510(k) clearance information. | 2006 | KGN (dressing, wound, collagen) | “Medline's Collagen Wound Dressing is indicated for the management of wounds including: full thickness and partial thickness wounds, pressure ulcers, venous ulcers, ulcers caused by mixed vascular etiologies, diabetic ulcers, partial and full thickness burns, donor sites and other bleeding surface wounds, abrasions, traumatic wounds healing by secondary intention, and dehisced surgical incisions. These dressings may be cut to size and may be layered for the management of deep wounds.”
Oasis - Cook Biotech, Inc.39 | Extracellular matrix derived from porcine small intestinal submucosa | 2006 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled, undermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, second-degree burns, and skin tears); draining wounds.”
Primatrix – TEI Biosciences Inc.40 | Acellular dermal tissue matrix. | 2008 | KGN (dressing, wound, collagen) | “For the management of wounds that include: partial and full thickness wounds; pressure, diabetic, and venous ulcers; second-degree burns; surgical wounds–donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence; trauma wounds–abrasions, lacerations, and skin tears; tunneled/undermined wounds; and draining wounds.”
Primatrix™ Dermal Repair Scaffold - TEI Biosciences41 | Extracellular matrix dermal substitute derived from fetal bovine dermis collagen. | 2006 | KGN (dressing, wound, collagen) | “For the management of wounds that include: partial and full thickness wounds; pressure, diabetic, and venous ulcers; second degree burns; surgical wounds-donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence; trauma wounds-abrasions, lacerations, and skin tears; tunneled/undermined wounds; draining wounds.”
SIS Wound Dressing II – Cook Biotech, Incorporated42 | A wound dressing primarily composed of porcine collagen. | 2000 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
SS Matrix™ – Cook Biotech Incorporated43 | A matrix product primarily composed of porcine collagen. | 2002 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
Stimulen™ Collagen – Southwest Technologies, Inc.44 | A sterile primary single use dressing comprised of soluble modified bovine collagen base. | 2004 | KGN (dressing, wound, collagen) | “For the management of wounds including full and partial thickness wounds, pressure ulcers (stages I-IV), venous stasis ulcers, diabetic ulcers, partial thickness burns, acute wounds, abrasions, traumatic wounds healing by secondary intention, donor sites and other surface wounds.”
TheraForm™ Standard/Sheet – Sewon Cellontech Co., Ltd.45 | An absorbable collagen membrane derived from porcine. | 2009 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
Unite^®^ Biomatrix – Synovis Orthopedic and Woundcare, Inc.46 | A decellularized equine pericardial extracellular matrix (xenograft) | 2011 | KGN (dressing, wound, collagen) | “For the management of moderately to severely exudating wounds, including: partial and full thickness wounds, draining wounds, pressure sores/ulcers, venous ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds (e.g., abrasions, lacerations, partial thickness [second-degree] burns, skin tears), surgical wounds (e.g., donor sites/grafts, post-laser surgery, post-Mohs surgery, podiatric wounds, dehisced surgical incisions).”
Unite™ Biomatrix – Pegasus Biologics, Inc.47 | A collagen-based wound dressing consisting of decellularized, equine pericardium. | 2007 | KGN (dressing, wound, collagen) | “For the local management of moderately to heavy exuding wounds including: partial and full thickness wounds, draining wounds, pressures sores/ulcers, venous ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds (e.g., abrasions, lacerations, partial thickness burns, skin tears), surgical wounds (e.g., donor sites/grafts, post-laser surgery, post-Mohs surgery, podiatric wounds, dehisced surgical incisions).”

KGN and FRO are among the FDA product codes designated for unclassified pre-amendment devices

Table 9 Biosynthetic products regulated under the 510(k) process

Product and Manufacturer | Description | Clearance Date | FDA Product Code | FDA Intended Use/Indication for Use
Hyalomatrix KC Wound Dressing (Laserskin) - Anika Therapeutics48 | Hyalomatrix is a bilayered wound dressing composed of a nonwoven pad made of a benzyl esters of hyaluronic acid (HYAFF) and a semipermeable silicone membrane. | 2001 | MGP (dressing, wound and burn, occlusive) | “For the management of wounds in the granulation phase such as pressure ulcers, venous and arterial leg ulcers, diabetic ulcers, surgical incisions, second degree burns, skin abrasions, lacerations, partial-thickness grafts and skin tears, wounds and burns treated with meshed grafts. It is intended for use as a temporary coverage for wounds and burns to aid in the natural healing process.”
Hyalomatrix Wound Dressing - Anika Therapeutics49 | Hyalomatrix is a bilayered wound dressing composed of a nonwoven pad made of HYAFF 11 (a benzyl ester of hyaluronic acid) and a semipermeable silicone membrane. | 2007 | FRO (dressing, wound, drug) | “For the management of wounds including: partial and full-thickness wounds; second-degree burns; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled/undetermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, skin tears); and draining wounds.”
Jaloskin - Anika Therapeutics50 | Jaloskin is a semipermeable, transparent film dressing, composed of HYAFF 11 (a benzyl ester of hyaluronic acid) only | 2010 | FRO (dressing, wound, drug) | “For the management of superficial moderately exuding wounds including pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, skin tears) and first and second degree bums.”
Suprathel - Polymedics Innovations51 | Synthetic, biocompatible, and absorbable skin substitute made from polymers of lactic acid. | 2009 | FRO (dressing, wound, drug) | “For temporary coverage of non-infected skin defects, such as superficial wounds, under sterile conditions. The dressing is intended to maintain a moist wound healing environment. A moist wound healing environment allows autolytic débridement. The Suprathel Wound and Burn Dressing is used in the management of: Partial and full thickness wounds; Pressure (stage I and IV) and venous ulcers; Ulcers caused by mixed vascular etiologies; Venous stasis and diabetic ulcers; 1st and 2nd degree bums; Partial thickness bums; Cuts and abrasions; Acute wounds; Trauma wounds; Surgical wounds; Superficial wounds; Grafted wounds and donor sites.”
Talymed™ – Marine Polymer Technologies, Inc.52 | A sterile wound matrix comprised of shortened fibers of poly-N-acetylglucosamine, isolated from microalgae. | 2010 | FRO (dressing, wound, drug | “For the management of wounds including: diabetic ulcers; venous ulcers; pressure wounds; ulcers caused by mixed vascular etiologies; full thickness and partial thickness wounds; second degree burns; surgical wounds-donor sites/grafts, post-Mohs surgery, post laser surgery, and other bleeding surface wounds; abrasions, lacerations; traumatic wounds healing by secondary intention; chronic vascular ulcers; dehisced surgical wounds.”

KGN, MGP, and FRO are among the FDA product codes designated for unclassified pre-amendment devices.

HYAFF: Benzyl esters of hyaluronic acid

Human tissue can be obtained from human donors, processed, and used exactly in the same role in the recipient—skin for skin, tendon for tendon, bone for bone. These uses are regulated as human tissue intended for transplantation (HCT/Ps) as long as the proposed clinical use and manufacturing methods are consistent with definitions of “Homologous Use” and “Minimal Manipulation” cited in 21 CFR 1271. Human tissue and cells may also be used as a source of cells for culturing to produce cellular-derived material for wound healing. These products may be regulated under the Biologics License Application (BLA) (under the PHS Act) or PMA/HDE (under the FD&C Act), depending on their composition and primary mode of action.

A number of medical products for treating wounds are derived from animal sources. Porcine and ovine tissues and skin are processed into sheets for use as skin substitutes. Bovine fetal tissue is a source of skin cells that are grown in culture to produce skin substitutes. Wound care products produced from these sources may be regulated under the 510(k) process if there is an appropriate predicate device with an equivalent composition and Intended Use and the proposed product does not raise any different types of safety or effectiveness questions. When a product does not meet these criteria, it may be reviewed in BLA or PMA/HDE applications, depending on the composition and primary mode of action.

Some skin substitute products are made from synthetic material that mimics skin properties. Similar to products derived from animal sources, products derived from synthetic material may be regulated under the 510(k) process if there is an appropriate predicate device with an equivalent composition and Intended Use and the proposed product does not raise any different types of safety or effectiveness questions. When a product does not meet these criteria, it may be reviewed in BLA or PMA/HDE applications, depending on the composition and primary mode of action.

Wound care products regulated under PMA are indicated for treating a subset of chronic wounds, those wounds with a duration greater than 30 days that have not adequately responded to standard wound care. The indications for 510(k) are not as strict. These products are indicated for managing chronic wounds and no restrictions are put on wound duration or prior treatments. Wound dressings cleared under the 510(k) process (or Class I exempt products) are considered to function by providing a moist wound healing environment. Since a moist wound environment is generally considered essential for the proper healing of most wound types these products are commercially distributed with a broad indication for use: “partial and full-thickness wounds; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled/undermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, second-degree burns, and skin tears); draining wounds.” This wording appears in most of the products regulated under the 510(k) process (see Table 8). When seeking claims beyond providing a moist wound healing environment, a legally marketed predicate device may not exist and clearance through the 510(k) process may not be possible. Therefore, determining whether a PMA or 510(k) application is appropriate is based upon both product composition and claims of product performance.

The information in Table 7 indicates that skin substitute products using human fibroblasts and keratinocytes (derived from neonatal foreskins) and combined with other acellular components are regulated under the PMA process and received FDA product code MGR (dressing, wound and burn, interactive). For these products the term “treatment” is used in the indications for use with chronic wounds. Each of the entries in Table 7 is actually a combination of living human cells and another component (bovine collagen in Apligraf and polyglactin mesh in Dermagraft). FDA considers these Combination Products, a combination of device and biological components into a single entity, and they are regulated as a medical device. Besides providing a biologic wound covering, these products also contain human cells capable of producing human growth factors and cytokines that may stimulate angiogenesis, tissue expansion, and re-epithelialization during the healing process.5 Thus, these products have the potential to be interactive with the wound bed and assist in the wound healing process.

The information in Table 8 and Table 9 indicates that skin substitute products considered Class II devices and regulated under the 510(k) process are included in FDA product codes KGN (dressing, wound, collagen), FRO (dressing, wound, drug), and MGP (dressing, wound and burn, occlusive) and use the term “management” of wounds in the indications for use on chronic wounds. These products use animal tissue collagen or synthetic material to create an extracellular matrix that acts as a wound covering and scaffold for tissue invasion and regrowth. They do not contain human cells and, therefore, do not have a natural source of growth factors or cytokines involved in initiating the wound healing process. The actual extent to which any one growth factor or cytokine is essential for wound repair has not been determined.5

We did identify one exception to the above scheme. EndoForm Dermal Template derived from ovine forestomach, and included in FDA product code KGN, is an exception to the use of the term “management” of wounds and instead uses the term “treatment” in the indications for use (see Table 8). The wording of the indications for use of EndoForm is almost identical to the wording used for Integra, MatriStem, Oasis, Primatrix, and Hyalomatrix but “treatment” is substituted for “management.” The reason for this difference is unclear.

## Human-Derived Products Regulated Solely Under the 21 CFR 1271

### AlloDerm^®^ Regenerative Tissue Matrix (LifeCell Corp., a KCI Company)

AlloDerm Regenerative Tissue Matrix is an acellular human dermis product. Donated human skin tissue is supplied by US American Association of Tissue Banks (AATB)-compliant tissue banks and processed into the dermis product. During processing, cells are removed and the product is freeze-dried. The LifeCell Web site promotes AlloDerm for hernia and breast reconstruction. According to packaging instructions for use, “AlloDerm is to be used for repair or replacement of damaged or inadequate integumental tissue or for other homologous uses of human integument.”120 LifeCell Corp. (Branchburg, NJ, USA) is registered with FDA as an establishment producing HCT/Ps.

### Allopatch HD™ (Musculoskeletal Transplant Foundation Sports Medicine)

Allopatch HD is an acellular human dermis designed to provide an extracellular matrix scaffold for tendon augmentation.121 The Musculoskeletal Transplant Foundation (Edison, NJ, USA) is registered with FDA as an establishment producing HCT/Ps.

### Alloskin™ (AlloSource)

Alloskin is a specialty allograft derived from epidermal and dermal cadaveric tissue and designed for wound care. AlloSource (Centennial, CO, USA) has several sites throughout the United States and is registered with FDA as an establishment producing HCT/Ps.122

### Cymetra^®^ Micronized AlloDerm (LifeCell Corp., a KCI Company)

Cymetra is an injectable form of AlloDerm Regenerative Tissue Matrix. Cymetra is micronized particulate form of AlloDerm that still contains the collagens, elastin, proteins, and proteoglycans that are present in AlloDerm.123 LifeCell Corp. (Branchburg, NJ, USA) is registered with FDA as an establishment producing HCT/Ps.

### DermaCell^®^ (LifeNet Health, Inc.)

DermaCell is a decellularized human dermis allograft designed for reconstruction surgical applications including chronic nonhealing wounds. DermaCell is provided by the Skin and Wound Allograft Institute, which is a wholly owned subsidiary of LifeNet Health. The company believes its MatraCell processing technology creates a readily available, extracellular matrix that then provides a collagen scaffold to support cell ingrowth.124 LifeNet Health, Inc. (Virginia Beach, VA, USA), is registered with FDA as an establishment producing HCT/Ps.

### Flex HD^®^ (Ethicon and Musculoskeletal Transplant Foundation)

Flex HD is an acellular hydrated dermis derived from donated human allograft skin. The skin is processed to remove the epidermis and dermal cells while preserving the acellular matrix of the dermis. The Musculoskeletal Transplant Foundation (MTF) acquires and processes the tissue. MTF has multiple sites throughout the United States.125 Ethicon sells Flex HD for hernia repair and breast reconstruction.126 The Musculoskeletal Transplant Foundation (Edison, NJ, USA) is registered with FDA as an establishment producing HCT/Ps.

### GammaGraft^®^ (Promethean LifeSciences, Inc.)

GammaGraft is an irradiated cadaveric human skin allograft designed to be a temporary graft for treating wounds including venous stasis ulcers, diabetic foot ulcers, and full-thickness wounds. Irradiating the graft preserves and sterilizes the tissue. The graft is stored in an aluminum foil package and preserved in a penicillin/gentamycin solution. To use GammaGraft the wound area is débrided, the graft is placed and a nonadherent dressing is applied, followed by a gauze dressing.127 Promethean LifeSciences, Inc. (Pittsburgh, PA, USA), is registered with FDA as an establishment producing HCT/Ps.

### Graftjacket^®^ Regenerative Tissue Matrix and Graftjacket^®^ Xpress (Manufactured by LifeCell Corp., Licensed to Wright Medical Technology, Inc., and Licensed to KCI)

Graftjacket Regenerative Tissue Matrix is a processed human dermal matrix designed to provide a scaffold for wound repair. Donated human tissue is treated to remove the epidermis and cellular components, but it retains collagen, elastin, and proteoglycans, and the internal matrix of the dermis remains intact. The tissue is then cryogenically preserved. The company states that removal of the cellular component reduces rejection, retention of dermal proteins allows for revascularization and cellular repopulation, and the preserved tissue matrix reduces inflammation. Graftjacket Xpress is micronized tissue scaffold designed to be used in tunneling ulcers.128 Wright Medical Technology, Inc. (Arlington, TN, USA), is registered with FDA as an establishment producing HCT/Ps.

### Matrix HD™ (RTI Biologics)

Matrix HD is a sterile acellular human dermis designed for reconstructive surgery and for treating chronic skin wounds. RTI Biologics (Alachua, FL, USA) is registered with FDA as an establishment producing HCT/Ps.129

### Memoderm™ (Memometal, Inc.)

Memoderm is a sterile acellular dermal matrix derived from human allograft skin tissue. Memometal, Inc. (Memphis, TN, USA), is registered with FDA as an establishment producing HCT/Ps.130

### Puros^®^ Dermis (Zimmer Dental)

Puros Dermis Allograft Tissue Matrix is a natural biological matrix designed for soft tissue augmentation, periodontal/peri-implant soft tissue management, and guided tissue regeneration procedures. The tissue is treated using the Tutoplast sterilization procedure to kill bacteria, destroy cells, remove prions, and reduce potential tissue rejection. The manufacturer's Web site does not specifically state if Puros Dermis is derived from human tissue, although this may be implied.131 Puros Dermis does not have 510(k) clearance or premarket approval, suggesting that this is a human-derived tissue product. Zimmer Dental is not registered with FDA as an establishment producing HCT/Ps but Zimmer Spine is registered.

### Repliform^®^ (LifeCell Corp./Boston Scientific Corp.)

Repliform Tissue Regeneration Matrix is a human acellular dermis. The donor human skin is processed and then freeze-dried to remove cells while maintaining the collagen, elastin, and proteoglycans. Repliform is processed by LifeCell Corp. and distributed by Boston Scientific Corp. The Boston Scientific Web site promotes Repliform for pelvic floor repair and says it “is intended for the repair or replacement of damaged or inadequate integumental tissue such to repair enteroceles, rectoceles and/or cystoceles and for pelvic floor reinforcement.”132 LifeCell Corp. (Branchburg, NJ, USA) is registered with FDA as an establishment producing HCT/Ps. LifeCell also produces AlloDerm, which seems to be the same product as Repliform.

### TheraSkin^®^ (Soluble Systems)

TheraSkin is a biologically active, cryopreserved human skin allograft, composed of living cells, fibroblasts, and keratinocytes and a fully developed extracellular matrix. TheraSkin does not contain any synthetic or animal materials. According to the company Web site, TheraSkin is designed to promote wound healing by providing cellular and extracellular components with growth factors, cytokines, and collagen and to be a natural barrier to infection. TheraSkin may be used in diabetic foot ulcers, venous stasis ulcers, and pressure ulcers. TheraSkin is marketed by Soluble Systems, and tissue is provided by the Skin and Wound Allograft Institute (SWAI), a wholly-owned subsidiary of LifeNet Health, Inc. SWAI (Virginia Beach, VA, USA) is registered with FDA as an establishment producing HCT/Ps.133

## Human-Derived Products Regulated Through Premarket Approval Process

### Apligraf/Graftskin (Organogenesis)

Apligraf is a living, cell-based, bilayered skin substitute designed to treat chronic venous leg ulcers and diabetic foot ulcers. The lower layer contains bovine type 1 collagen and human fibroblasts to form a dermis-like structure that produces additional matrix proteins. Human keratinocytes form an epidermal layer to replicate the structure of the human epidermis. The human keratinocytes and fibroblasts are derived from neonatal foreskins. Apligraf is believed to stimulate the patient's own cells to regenerate tissue and heal the wound through mechanisms that may include the secretion of growth factors, cytokines, and matrix proteins. Apligraf does not contain melanocytes, Langerhans' cells, macrophages, lymphocytes, or tissue structures such as blood vessels, hair follicles, and sweat glands. Apligraf is manufactured by Organogenesis (Canton, MA, USA).134

In December 1998, FDA approved Apligraf for marketing under the PMA process for “use with standard therapeutic compression for the treatment of noninfected partial and full-thickness skin ulcers due to venous insufficiency of greater than 1 month duration and which have not adequately responded to conventional ulcer therapy.” Multiple supplements have been added since the first approval, including an indication for treating diabetic foot ulcers. Several of the supplements involve approval for the use of new human keratinocyte or fibroblast cell strains in the manufacture of Apligraf. Apligraf is included in FDA product code MGR (dressing, wound and burn, interactive).135

### Dermagraft (Advanced Biohealing, Inc./Smith & Nephew)

Dermagraft is a cryopreserved, human fibroblast-derived dermal substitute containing fibroblasts, extracellular matrix, and a bioabsorbable polyglactin mesh scaffold. The fibroblasts are obtained from human newborn foreskin tissue. The fibroblasts are placed on the scaffold and then proliferate and produce human dermal collagen, matrix proteins, growth factors, and cytokines. The process creates a three-dimensional human dermal substitute with metabolically active human cells. Dermagraft does not contain macrophages, lymphocytes, blood vessels, or hair follicles. It comes frozen as a single sheet (2 by 3 inches) for a single application.136 In May 2006, Advanced BioHealing purchased the global rights to Dermagraft from Smith & Nephew.

In September 2001, FDA approved Dermagraft for marketing under the PMA process for “use in the treatment of full-thickness diabetic foot ulcers greater than six weeks' duration which extend through the dermis, but without tendon, muscle, joint capsule or bone exposure. Dermagraft® should be used in conjunction with standard wound care regimens and in patients that have adequate blood supply to the involved foot.” Dermagraft is included in FDA product code MGR (dressing, wound and burn, interactive). Advanced BioHealing, Inc. (La Jolla, CA, USA), is registered with FDA as an establishment producing HCT/Ps.137

## Animal-Derived Products Regulated Through the 510(k) Process

The FDA product code KGN contains wound dressings based on collagen. Collagen-based dressings contain purified collagen derived primarily from bovine or porcine sources. The type and concentration of collagen varies depending on the actual dressing. Rather than just providing structural support within a wound, collagen is now believed to play a critical role in all aspects of wound healing. When a wound is first formed, platelets aggregate around exposed collagen. The platelets release a variety of growth factors and cytokines that attract inflammatory cells (macrophages, neutrophils, eosinophils) to the wound. The inflammatory cells degrade collagen and other protein debris in the wound, and at the same time, produce factors that attract and stimulate fibroblast activity. Fibroblasts secrete matrix metalloproteinase (MMP) along with collagen and produce factors that attract additional fibroblasts as well as epithelial cells and vascular endothelial cells into the wound. These cells then produce the granulation tissue that forms the extracellular matrix. The MMPs are responsible for degrading nonviable collagen while the new matrix is forming. However, in chronic wounds, fibroblasts may produce too much MMP and too little of the factors that inhibit MMPs. When this occurs, the MMPs may destroy new, viable collagen and prevent proper wound healing. Collagen-based dressings are believed to aid wound healing by stimulating fibroblast production and have a hydrophilic property that enhances fibroblast movement and inhibition and deactivation of MMPs.90 FDA product code KGN contains a variety of wound dressings that use collagen in some form as the primary component of the dressing. The following is a description of some of these wound dressings. Table 8 contains a list of the wound dressings indicated for chronic wounds under product code KGN.

### EndoForm (Mesynthes, Ltd.)

EndoForm Dermal Template is an extracellular matrix derived from ovine forestomach. According to the company Web site, “Endoform™ is a proprietary biomaterial containing a rich and complex mix of important biological extracellular matrix (ECM) molecules, including structural (collagens I, III, IV & elastin) and adhesive proteins (fibronectin and laminin), glycosaminoglycans (heparin sulfate and hyaluronic acid) and growth factors (FGF2 & TGFß).”138

EndoForm Dermal Template (Mesynthes, Ltd., North Attleboro, MA, USA, and Wellington, New Zealand) was cleared for marketing under the 510(k) process (K092096) in January 2010 for “single use in the treatment of the following wounds: partial and full-thickness wounds; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled/undermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, second-degree burns, and skin tears); draining wounds.” EndoForm Dermal Template is included in FDA product code KGN (dressing, wound, collagen).27

### E-Z Derm (AM Scientifics, Ltd.)

E-Z Derm is a biosynthetic wound dressing made from porcine tissue chemically treated to cross-link collagen with an aldehyde to add strength and allow storage at room temperature. Because E-Z Derm is composed of porcine tissue, it is considered a porcine xenograft. The shelf life is 18 months. The company Web site promotes E-Z Derm for the temporary coverage of wounds prior to autograft, partial thickness skin loss, to protect meshed autografts, for outpatient skin loss, donor sites, skin ulcerations, and abrasions.139

E-Z Derm Biosynthetic Wound Dressing (Brennen Medical, Inc., St. Paul, MN, USA) was cleared for marketing under the 510(k) process in July 1994 (K935189, no summary available). E-Z Derm is included in FDA product code KGN (dressing, wound, collagen).26

### Integra Bilayer Matrix Wound Dressing (Integra Lifesciences Corp.)

Integra is a bilayered matrix wound dressing composed of a porous layer of cross-linked bovine tendon collagen and glycosaminoglycan and a semipermeable polysiloxane (silicone) layer. According to the company Web site, the silicone layer allows for controlled water vapor loss and provides a flexible covering for the wound surface. The collagen-glycosaminoglycan matrix is biodegradable and provides a scaffold for cell entry and capillary growth. The silicone membrane is temporary and the collagen-glycosaminoglycan matrix is remodeled as the wound area is repaired. Integra can be stored at room temperature.140

In April 2001, FDA approved Integra dermal regeneration template for marketing under the PMA process “for the post excisional treatment of life-threatening full-thickness or deep partial-thickness thermal injury where sufficient autograft is not available at the time of excision or not desirable due to the physiological condition of the patient.” Bilayer Matrix Wound Dressing (Integra LifeSciences Corp., Plainsboro, NJ, USA) was cleared for marketing under the 510(k) process in August 2002 (K021792) and is indicated “for the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic and vascular ulcers, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds. This device is intended for one-time use.” Integra is included in FDA product code FRO (dressing, wound, drug).32

### MatriStem (ACell, Inc.)

MatriStem Wound Care Matrix is an extracellular matrix product derived from porcine urinary bladder tissue and designed to be replaced by native tissue in the wound.141 ACell MatriStem Wound Sheet (ACell, Inc., Columbia, MD, USA) was cleared for marketing under the 510(k) process in October 2009 (K092926) and “is intended for the management of wounds that including: partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, skin tears) and draining wounds. The device is intended for one-time use.” MatriStem is included in FDA product code KGN (dressing, wound, collagen). MatriStem Wound Care Matrix was cleared for marketing under the 510(k) process in August 2010 (K112409) with MatriStem Wound Sheet as the predicate device and with the same indications.35

### Oasis Wound Matrix (Cook Biotech, Inc.)

Oasis Wound Matrix is an extracellular matrix derived from porcine small intestinal submucosa. According to the company Web site, the intestinal material is absorbed into the wound during the healing process. Oasis is applied to wounds after débridement. The edges of the Oasis sheet extend beyond the wound edges and are secured with tissue sealant, bolsters, dissolvable clips, sutures, or staples. The sheet is rehydrated with sterile saline and covered with a nonadherent, primary wound dressing followed by a secondary dressing to contain exudate. Oasis is reapplied every 7 days or as needed.142

Oasis Wound Matrix (Cook Biotech, Inc., West Lafayette, IN, USA) was cleared for marketing under the 510(k) process in July 2006 (K061711) and is indicated “for the management of wounds including: partial and full-thickness wounds; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled, undermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, second-degree burns, and skin tears); draining wounds. The device is intended for one-time use.” Oasis is included in FDA product code KGN (dressing, wound, collagen).39

### Primatrix (TEI Biosciences, Inc.)

Primatrix is an animal-derived, extracellular matrix dermal substitute intended to act as a scaffold to allow cell and vascular penetration. According to the company Web site, TEI biological matrix products are derived from fetal bovine dermis collagen. In producing this product, the epidermis, hair, muscle, and fascia are removed. The dermis is then treated to remove cells and infectious agents while preserving biological properties and structures. The product is converted to sheets, freeze dried, and sterilized. When applied to a wound, the product is rehydrated. The company believes that the high concentration of type III collagen in its product may assist in the wound healing process.143

Primatrix Dermal Repair Scaffold (TEI Biosciences, Inc., Boston, MA, USA) was cleared for marketing under the 510(k) process in June 2006 (K061407) and “is intended for the management of wounds that include: partial and full thickness wounds; pressure, diabetic, and venous ulcers; second degree burns; surgical wounds-donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence; trauma wounds-abrasions, lacerations, and skin tears; tunneled/undermined wounds; draining wounds.” Primatrix is included in FDA product code KGN (dressing, wound, collagen).41

## Biosynthetic Products Regulated Through the 510(k) Process

### Hyalomatrix, Laserskin^®^, and Jaloskin^®^ (Anika Therapeutics, Inc.)

Hyalomatrix (see Hyalomatrix PA below) is a bilayered wound dressing composed of a nonwoven pad made of a benzyl ester of hyaluronic acid (HYAFF 11) and a semipermeable silicone membrane. The nonwoven pad contacts the wound and, according to the company Web site, “provides a three dimensional matrix for cellular invasion and capillary growth.” The silicone membrane “controls water vapor loss, provides a flexible covering for the wound surface, and adds increased tear strength to the device.” The HYAFF 11 matrix is biodegradable. The company believes that “when the integration of the HYAFF based material in the newly formed dermal matrix has progressed, a well-vascularized granulation tissue forms. This provides for wound closure via spontaneous re-epithelialization or acts as a suitable dermal layer for skin grafting.”144

Hyalomatrix KC Wound Dressing (Anika Therapeutics, Inc., Bedford, MA, USA, formerly Fidia Advanced Biopolymers, Abano Terme, Italy) was cleared for marketing under the 510(k) process in July 2001 (K001508) for “the management of wounds in the granulation phase such as pressure ulcers, venous and arterial leg ulcers, diabetic ulcers, surgical incisions, second degree burns, skin abrasions, lacerations, partial-thickness grafts and skin tears, wounds and burns treated with meshed grafts. It is intended for use as a temporary coverage for wounds and burns to aid in the natural healing process.” Hyalomatrix KC Wound Dressing is included in FDA product code MGP (dressing, wound and burn, occlusive). In the FDA 510(k) database, number K001508 refers to Laserskin Dressing as the device; however, in the 510(k) summary for K001508, the proprietary name is Hyalomatrix KC Wound Dressing and the name Laserskin is not mentioned.48

Hyalomatrix PA Wound Dressing (Anika Therapeutics, Inc., Bedford, MA, USA) was cleared for marketing under the 510(k) process in December 2007 (K073251). The company refers to Hyalomatrix PA by its trade name Hyalomatrix. In the 510(k) documents Hyalomatrix is described as a bilayered dressing composed of a nonwoven pad made of HYAFF 11 and a semipermeable silicone membrane. Hyalomatrix “is indicated for the management of wounds including: partial and full-thickness wounds; second-degree burns; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled/undetermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, skin tears); and draining wounds. The device is intended for one-time use.” Hyalomatrix is included in FDA product code FRO (dressing, wound, drug). The predicate device was “Hyalomatrix KC (Laserskin) Wound Dressing.”49

Jaloskin (Anika Therapeutics, Inc., Bedford, MA, USA) was cleared for marketing under the 510(k) process in January 2010 (K092257) for “the management of superficial moderately exuding wounds including pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, skin tears) and first and second degree bums.” Jaloskin is a semipermeable, transparent film dressing, composed of HYAFF 11 only. The hyaluronic acid is derived from bacterial fermentation. Jaloskin is included in FDA product code FRO (dressing, wound, drug).50

Anika Therapeutics, Inc. (Bedford, MA, USA), acquired Fidia Advanced Biopolymers S.r.l. (currently Anika Therapeutics S.r.l.) in December 2009. The Anika Therapeutics Web site advertises Hyalomatrix and Jaloskin.

### Suprathel^®^ (Polymedics Innovations GmbH)

Suprathel is a synthetic, biocompatible, and absorbable skin substitute made from polymers of lactic acid. The Suprathel membrane is applied once to a clean débrided wound surface and then breaks down during the healing process. According to the company Web site, the products of Suprathel degradation stimulate the healing process by increasing angiogenesis and rebuilding the dermis. The acidification of the wound bed by breakdown products is also supposed to have a bactericidal effect.145

Suprathel Wound and Burn Dressing (Polymedics Innovations GmbH, Denkendorf, Germany) was cleared for marketing under the 510(k) process (K090160) in May 2009 for “temporary coverage of noninfected skin defects, such as superficial wounds, under sterile conditions. The dressing is intended to maintain a moist wound healing environment. A moist wound healing environment allows autolytic débridement. The Suprathel Wound and Burn Dressing is used in the management of: Partial and full thickness wounds; Pressure (stage I and IV) and venous ulcers; Ulcers caused by mixed vascular etiologies; venous stasis and diabetic ulcers; 1st and 2nd degree burns; Partial thickness burns; cuts and abrasions; acute wounds; trauma wounds; surgical wounds; superficial wounds; grafted wounds and donor sites.” Suprathel is included in FDA product code FRO (dressing, wound, drug).51

### Talymed (Marine Polymer Technologies, Inc.)

Talymed is a sterile wound matrix comprised of shortened fibers of poly-N-acetylglucosamine, isolated from microalgae. Talymed (MARINE POLYMER TECHNOLOGIES, Danvers, MA, USA) was cleared for marketing under the 510(k) process (K102002) in July 2010 for “the management of wounds including: diabetic ulcers; venous ulcers; pressure wounds; ulcers caused by mixed vascular etiologies; full thickness and partial thickness wounds; second degree burns; surgical wounds-donor sites/grafts, post-Mohs surgery, post laser surgery, and other bleeding surface wounds; abrasions, lacerations; traumatic wounds healing by secondary intention; chronic vascular ulcers; dehisced surgical wounds.” Talymed is included in FDA product code FRO (dressing, wound, drug).52

## Products Not Yet Available in the United States for Treating Chronic Wounds

### Celaderm (Advanced Biohealing, Inc.)

Advanced BioHealing, Inc., sponsored a clinical trial of Celaderm for treating venous leg ulcers, and information about the trial was available on ClinicalTrials.gov. Celaderm was described as a frozen, cultured, epidermal allograft. Advanced BioHealing, Inc. (La Jolla, CA, USA) is registered with FDA as an establishment producing HCT/Ps. Information on this device was not available on the company or FDA Web sites.146

### Dermagen (Laboratoires Genévrier, France)

Dermagen is a “sponge composed of collagen and glycosaminoglycans (chondroitins 4 and 6 sulphate), reticulated by ionic bonds with chitosan” under investigation for treating diabetic neuropathic foot ulcers. The study is ongoing with all locations in France but not recruiting participants. Dermagen is made by Laboratoires Genévrier, Antibes, France.147

### Epicel (Genzyme)

Epicel is a cultured epidermal autograft intended to treat deep dermal or full-thickness burns. According to the product labeling, “Epicel® cultured epidermal autografts (CEA) is an aseptically processed wound dressing composed of the patient's own (autologous) keratinocytes grown ex vivo in the presence of proliferation-arrested, murine (mouse) fibroblasts. Epicel® consists of sheets of proliferative, autologous keratinocytes, ranging from 2 to 8 cell layers thick and is referred to as a cultured epidermal autograft.” Epicel is created by co-cultivation of the patient's cells with murine cells and contains residual murine cells. Therefore, FDA considers Epicel a xenotransplantation product.148

Epicel (Genzyme Biosurgery, Cambridge, MA, USA) was granted an humanitarian device exemption (HDE) by FDA in October 2007 and is “indicated for use in patients who have deep dermal or full thickness burns comprising a total body surface area of greater than or equal to 30 percent. It may be used in conjunction with split-thickness autografts, or alone in patients for whom split-thickness autografts may not be an option due to the severity and extent of their burns.”149

### Epidex (Euroderm AG)

Epidex is a skin product generated from keratinocytes from the patient's hair follicles. Epidermal sheets are created with silicone membrane support.5 Euroderm AG (Baden-Dättwil, Switzerland) seems to be strictly a European company. None of its skin products seem to be sold in the United States and it has no listing with FDA.150

### Matriderm (Dr. Suwelack Skin and Health Care AG)

Matriderm is a collagen-elastin matrix designed to support dermal regeneration after severe skin injuries. The matrix provides a structure for the invasion of native cells to regenerate the dermis. After placement, Matriderm is covered with a very thin, split-thickness, skin graft. The company Web site promotes Matriderm for treating severe burn injuries.151

This product does not seem to be available in the United States and is not listed on the FDA Web site. A company called Suwelack Matrix Systems, Inc., Stony Brook, NY, USA, was established in 2005 but does not have any products listed on the FDA Web site.

### OrCel (Forticell Bioscience, Inc.)

OrCel is a bilayered, cellular matrix composed of normal, human, allogeneic, epidermal keratinocytes and dermal fibroblasts. The cells are cultured in two separate layers into a type I bovine collagen sponge. Neonatal human fibroblasts and keratinocytes are obtained from the same donor. According to the company Web site, the matrix is designed to provide a structure for host cell invasion along with a mix of cytokines and growth factors. The matrix is absorbed as the wound heals. Because of the extensive culturing process, the cells do not express the antigens responsible for rejection. The cells produce growth factors. A PMA application with FDA has been filed for treating venous leg ulcers. Studies will test OrCel in treating diabetic foot ulcers. The company Web site indicates that it will promote OrCel for treating chronic and acute wounds. Forticell Bioscience, Inc., is the former Ortec International, Inc.152

Composite Cultured Skin (Ortec International, Inc., New York, NY, USA) was granted an HDE by FDA in February 2001 and is “indicated for use in patients with mitten hand deformities due to Recessive Dystrophic Epidermolysis Bullosa (RDEB) as an adjunct to standard autograft procedures (i.e., skin grafts and flaps) for covering wounds and donor sites created after the surgical release of hand contractures (i.e., “mitten” hand deformities).”153 OrCel has also received PMA approval for treating fresh, clean, split-thickness, donor site wounds in burn patients and may, therefore, be used by physicians off-label on chronic wounds.

### PermaDerm (Regenicin)

PermaDerm is under development as a tissue-engineered skin prepared from the patient's own skin cells (autologous). A section of the patient's skin containing both epidermis and dermis is harvested and grown into a graft to cover a large wound area. The process takes 30 days. The product is being developed for burns and chronic wounds. Regenicin (Little Falls, NJ, USA) is working on a PMA application with FDA.154

### StrataGraft/ExpressGraft (Stratatech Corp.)

StrataGraft for severe burns and ExpressGraft for diabetic foot ulcers and venous leg ulcer are skin substitutes under development at Stratatech Corp. (Madison, WI, USA). According to the company Web site, “Stratatech is a regenerative medicine company focused on the commercialization of novel skin substitute products for therapeutic and research use.” StrataGraft is “designed to mimic natural human skin, with both dermal and fully differentiated epidermal layers.” ExpressGraft tissues are being developed as “genetically enhanced tissues that produce elevated levels of natural wound healing and anti-microbial factors.” These products are not yet commercially available.155

### Xelma (Mölnlycke Healthcare, Gothenburg, Sweden)

Xelma is an extracellular matrix protein (amelogenins) contained in propylene glycol alginate and water designed to treat wounds, primarily venous leg ulcers. Xelma is applied topically and then covered with a secondary dressing. According to the company Web site, Xelma “temporarily replaces the damaged extracellular matrix proteins” in the wound and promotes “restoration of the cellular and biochemical balance … which will promote granulation tissue formation and normal wound healing.”156 Xelma was not listed on the Mölnlycke Healthcare USA or FDA Web sites.

## Key Question 2 For patients with chronic wounds (pressure ulcers, diabetic foot ulcers, venous leg ulcers, or arterial leg ulcers) are skin substitutes more effective than other wound care options (usual care, standard care, synthetic dressings, growth factors, skin grafts, or other treatments used as a comparison) in promoting wound healing for the following outcome measures

a. Percentage of completely closed/healed wounds
b. Time to complete wound closure
c. Wound reoccurrence
d. Wound infection
e. Need for amputation
f. Need for hospitalization (frequency and duration)
g. Return to baseline activities of daily living and function
h. Pain reduction
i. Exudate and odor reduction

Our searches identified 18 RCTs that met our inclusion criteria (see Table 10). Twelve of the studies examined diabetic foot ulcers and six studies examined vascular leg ulcers. Only seven skin substitute products were examined in the RCTs that met our inclusion criteria. We identified only one study using skin substitutes to treat patients with pressure ulcers, but this study did not meet the inclusion criteria (see Table 20). Outcomes reported in these studies were primarily complete wound healing by 12 weeks (13 studies), time to complete wound healing (12 studies), complete wound healing after 12 weeks (9 studies), and wound infection (16 studies) (see Table 11). Complete wound healing was defined in these studies as full epithelialization with no drainage, no exudate or eschar (scab) present (see Table 49 to Table 53). Other outcomes listed in Key Question 2 were not as frequently reported and measures of function and activities of daily living were not reported in any study (see Table 12).

Table 10 List of included randomized controlled trials

Study | Comparison | Wound Type
DiDomenico et al. 2011^64^ | Apligraf vs. TheraSkin | DFU
Edmonds 2009^53^ | Apligraf vs. nonadherent dressing | DFU
Falanga et al. 1998^63^ | Apligraf with compression vs. compression | Leg, Venous
Krishnamoorthy et al. 2003^55^ | Dermagraft plus multilayered compression bandage therapy (Profore™) vs. multilayered compression therapy | Leg, Venous
Marston et al. 2003^56^ | Dermagraft vs. saline-moistened gauze | DFU
Naughton et al. 1997^62^ | Dermagraft vs. saline-moistened gauze | DFU
Gentzkow et al. 1996^65^ | Dermagraft vs. saline-moistened gauze | DFU
Reyzelman et al. 2009^66^ | Graftjacket acellular matrix vs. moist wound therapy with alginates, foams, hydrocolloids, or hydrogels | DFU
Brigido 2006^59^ | Graftjacket tissue matrix vs. weekly debridement, Curasol wound hydrogel and gauze dressing | DFU
Veves et al. 2001^67^ | Graftskin vs. saline-moistened gauze alone | DFU
Uccioli et al. 2011^68^ | Hyalograft 3D autograft/Laserskin vs. nonadherent paraffin gauze | DFU
Caravaggi et al. 2003^58^ | Hyalograft 3D autograft/Laserskin vs. nonadherent paraffin gauze | DFU
Romanelli et al. 2010^57^ | Oasis Wound Matrix vs. a petrolatum-impregnated gauze | Leg, Mixed
Landsman et al. 2008^54^ | Oasis Wound Matrix vs. Dermagraft | DFU
Romanelli et al. 2007^60^ | Oasis Wound Matrix vs. Hyaloskin (contains hyaluronan) | Leg, Mixed
Mostow et al. 2005^69^ | Oasis Wound Matrix with compression vs. compression alone | Leg, Venous
Niezgoda et al. 2005^70^ | Oasis Wound Matrix vs. Regranex Gel (contains platelet-derived growth factor) | DFU
Kelechi et al. 2011^61^ | Talymed poly-N-acetyl glucosamine (pGlcNAc) with compression vs. nonadherent absorptive primary dressing with compression | Leg, Venous

DFU: Diabetic foot ulcer

HYAFF: Benzyl esters of hyaluronic acid

Leg, Mixed: Venous and arterial leg ulcers

SOC: Standard of care

Table 11 List of wound healing outcomes reported by included studies

Skin Substitutes | References | Complete Wound Healing by 12 Weeks | Complete Wound Healing After 12 Weeks | Time to Complete Wound Healing | Wound Reoccurrence After 12 Weeks | Wound Infection
Apligraf and Graftskin | Edmonds 2009^53^ | X | — | X | X | X
Apligraf and Graftskin | Veves et al. 2001^67^ | X | — | X | X | X
Apligraf and Graftskin | Falanga et al. 1998^63^ | — | X | X | X | X
Apligraf and TheraSkin | DiDomenico et al. 2011^64^ | X | X (20 weeks) | X | — | X
Dermagraft | Krishnamoorthy et al. 2003^55^ | X | — | — | — | X
Dermagraft | Marston et al. 2003^56^ | X | — | — | — | X
Dermagraft | Naughton et al. 1997^62^ | X | X | X | X | X
Dermagraft | Gentzkow et al. 1996^65^ | X | — | X | X | X
Graftjacket | Reyzelman et al. 2009^66^ | X | — | X | — | X
Graftjacket | Brigido SA. 2006^59^ | — | X | X | — | X
HYAFF (Benzyl esters of hyaluronic acid) | Uccioli et al. 2011^68^ | X | X (20 weeks) | X | — | X
HYAFF (Benzyl esters of hyaluronic acid) | Caravaggi et al. 2003^58^ | X (by 11 weeks) | — | X | — | X
Oasis | Romanelli et al. 2010^57^ | X (by 8 weeks) | — | X | — | X
Oasis | Landsman et al. 2008^54^ | X | — | X | — | —
Oasis | Romanelli et al. 2007^60^ | — | X (16 weeks) | — | — | —
Oasis | Mostow et al. 2005^69^ | X | X | | X | X
Oasis | Niezgoda et al. 2005^70^ | X | X | X | X | X
Talymed | Kelechi et al. 2011^61^ | — | X (20 weeks) | — | — | X

X indicates the study reported this outcome.

Table 12 List of other significant outcomes reported by included studies

Skin Substitutes | References | Need for Amputation | Need for Hospitalization | Measures of Function and Activities of Daily Living | Pain | Exudate | Odor
Apligraf and Graftskin | Edmonds 2009^53^ | X | | | | X
Apligraf and Graftskin | Veves et al. 2001^67^
Apligraf and Graftskin | Falanga et al 1998^63^ | | | | X | X
Apligraf and TheraSkin | DiDomenico et al. 2011^64^ | | X
Dermagraft | Krishnamoorthy et al. 2003^55^ | | X
Dermagraft | Marston et al. 2003^56^
Dermagraft | Naughton et al. 1997^62^
Dermagraft | Gentzkow et al. 1996^65^
Graftjacket | Reyzelman et al. 2009^66^
Graftjacket | Brigido SA. 2006^59^
HYAFF (Benzyl esters of hyaluronic acid) | Uccioli et al. 2011^68^ | X
HYAFF (Benzyl esters of hyaluronic acid) | Caravaggi et al. 2003^58^
Oasis | Romanelli et al. 2010^57^ | | | | X
Oasis | Landsman et al. 2008^54^
Oasis | Romanelli et al. 2007^60^ | | X
Oasis | Mostow et al. 2005^69^ | | | | X
Oasis | Niezgoda et al. 2005^70^
Talymed | Kelechi et al. 2011^61^ | | | | X

X indicates the study reported this outcome.

Two studies of Graftjacket (processed human dermal matrix) were the only RCTs examining HCT/Ps. Nine studies (4 for Apligraf and 5 for Dermagraft) examined products derived from humans and regulated through the PMA process (includes 1 study comparing Apligraf with TheraSkin and 1 study comparing Dermagraft with Oasis). Five studies of Oasis wound matrix were the only RCTs examining animal-derived products regulated under the 510(k) process. Three studies of Hyalograft 3D autograft were the only RCTs examining biosynthetic products regulated under the 510(k) process (including 1 study comparing Hyaloskin with Oasis). One RCT examined the efficacy of Talymed (algae-derived). The results obtained from studies of a single product, such as Graftjacket within HCT/Ps, cannot be extrapolated to all products in a group because of differences in product components and healing properties. Therefore, clinical evidence of efficacy obtained from RCTs is not available for most of the skin substitute products discussed in this report.

### Risk of Bias in the Evidence Base

No RCTs were considered at high risk of bias. However, the RCT by Naughton et al.62 was considered to have an unclear risk of bias primarily because of poor reporting of methods (most risk-of-bias assessment questions were answered with an NR). The other 17 RCTs were split between low (8 studies) and moderate (9 studies) risk of bias. No study specifically mentions blinding the wound assessor when complete wound healing was determined. Information on wound severity was reported in only two studies. Manufacturer funding did not seem to influence the reporting of key wound healing outcomes in the included RCTs.

#### Apligraf/Graftskin

All three studies of Apligraf/Graftskin conducted by Organogenesis were considered to have low risk for bias (Edmonds M. 2009,53 Veves et al. 2001,67 Falanga et al. 1998^63^). None of the publications reported on comorbidities, so information reported to FDA was used to fill in this information. A fourth study compared Apligraf to TheraSkin (DiDomenico et al. 2011^64^) and was considered to have moderate risk for bias because randomization methods, wound duration, and comorbidities were not reported and the study did not blind wound assessment (see Table 22).

#### Dermagraft

Three of the four Dermagraft studies were at a moderate risk for bias (see Table 23). Naughton et al.62 did not report any baseline information by which most of the risk-of-bias assessment questions could be answered and, therefore, was considered to have an unclear risk of bias. In the other studies, randomization method was either not reported or was not appropriate, and wound size, wound duration, and comorbidities were poorly reported.

#### Graftjacket

One study had a moderate risk of bias for not reporting randomization methods, concealment of group allocation, wound duration, or wound size.59 Reyzelman et al.66 was categorized as low risk after information provided by the author indicated use of appropriate randomization methods and concealment of treatment allocation (see Table 24).

#### Oasis

Four studies of Oasis were considered at moderate risk of bias; one study was considered at low risk of bias. Reporting of comorbidities was absent in all of the studies (see Table 26). Three studies with moderate risk of bias did not report or use appropriate randomization methods or concealment of allocation. In three of the studies, mean wound duration was not reported.

#### Hyalograft 3D autograft/Laserskin

Two studies evaluating Hyalograft 3D autograft/Laserskin were at a low risk of bias (see Table 25).

#### Talymed (pGlcNAc)

In this single study reporting comorbidities, appropriate randomization methods and wound duration led to a low risk of bias rating; however, although the investigators were blinded, the study did not report blinding of wound assessment (performed by study nurses)61 (see Table 25).

### Study Design, Patient Enrollment Criteria, Description of Treatment, Patient Characteristics

Information on study design and conduct, patient enrollment criteria, details on treatment, and the characteristics of patients in the studies are contained in Table 27 to Table 48 in Appendix C.

Several important areas of study design and patient information of interest to this report were poorly reported. Prior wound treatments were not reported in any of the studies, and reporting of comorbidities was sparse. Wound severity before enrolling in a study was reported in only two studies.

A run-in period to assess wound healing under standard care before allowing a patient to enter a study has been recommended because some wound healing may be due to improved adherence to standard treatment. FDA recommends excluding patients who demonstrate “substantial healing resulting solely from improved compliance with standard care.”10 The POWER group believes that a “run-in period is a way to normalize or equalize all subjects, making them comparable at the start of the test phase where appropriate.”108 Only 7 of the 18 studies included in this report mention using a run-in period before enrolling patients in the study (see Table 32). Five of the studies used a 2-week run-in period and two studies used a 1-week run-in period.

EWMA106 has recommended that “a unified outcome approach to wound assessment be established and put into practice. This would allow standardized data assessment across the whole range of clinical research evaluating the efficacy of current and emerging technologies in wound healing.” Table 33 describes the methods used at initial wound assessment. A variety of methods were used to determine initial wound size and to measure changes in wound size during the course of a study. Computerized planimetry was used in eight studies, typically in conjunction with photographs and/or tracings. None of the studies mentions training in wound assessment or validation of the methods.

Wound reassessment after initial complete healing is recommended by FDA, POWER, CMTP, and EWMA.10,106,108,113 The FDA definition for complete wound closure includes a requirement for reappraisal of wound closure at two consecutive study visits 2 weeks apart.10 FDA also recommends that “trial subjects remain in the study for followup evaluation at least 3 months following complete wound closure.” Such a followup period would allow determination of acceptable wound healing rather than minimal wound healing.2 Four of the studies included in this report reassessed completely healed wounds within 2 weeks of initial wound closure (see Table 32): Edmonds53, Landsman et al.54, Krishnamoorthy et al.55, and Marston et al.56 Eight studies used various followup methods that included wound reassessment biweekly, monthly, or every 3 months until the end of the study. Six studies did not mention reassessment or planned followup to assess the durability of wound closure.

Patients were generally excluded from studies if their health was suboptimal, they were taking medication that would interfere with wound healing, their wounds were infected, or the blood flow to the affected area was poor. Since Apligraf and Dermagraft are specifically not indicated for infected wounds (see Table 7), studies of these treatments would not include patients with infected wounds at the time of starting treatment with the skin substitute. Several studies also indicated they excluded patients who responded to usual care during screening periods (see studies of Apligraf, Dermagraft, Hyalograft autograft/Laserskin and Oasis described below for details). This procedure ensures that only patients with hard-to-heal chronic wounds are enrolled in the study.

Studies of vascular leg ulcers should enroll only patients with verified venous disease.157 Of the six studies of vascular ulcers, only Falanga et al. 1998^63^ reported using air plethysmography or photoplethysmography to determine venous insufficiency (see Table 34). The other studies did not mention steps taken to verify venous disease. Four studies included only patients with an ankle-brachial pressure index (ABI) above 0.7 to rule out arterial disease. Two studies by Romanelli et al.57,60 included mixed arterial and venous (A/V) leg ulcers and patients were included if they had an ABI between 0.6 and 0.8. Approximately half of the patients in these studies had mixed A/V leg ulcers. ABI values less than 0.5 indicate poor blood perfusion and predict difficult wound healing.86

Some form of ancillary wound treatment was provided to all enrolled patients. This treatment typically included usual care procedures such as debridement, saline-moistened dressings, and a nonweight-bearing regimen. Antibiotics were provided in several studies; two studies cited this as a requirement by current international guidelines.58,68

#### Apligraf/Graftskin

Three of the four studies of Apligraf/Graftskin were sponsored by Organogenesis, Inc., and examined between 72 and 293 patients; two studies were conducted in multiple U.S. centers.63,67 One study recruited patients in the European Union and Australia.53 Two studies examining patients with diabetic foot ulcers evaluated efficacy at 12 weeks during a study duration of 6 months,53,67 and one study examining venous leg ulcers evaluated efficacy at 6 months during a study duration of 12 months.63 Mean age ranged from 56 to 60 years. Two studies excluded patients who responded to usual care during 7- or a 14-day screening period.53,67 In the study with the 14-day screening period, the ulcer could not show a greater than 40 percent reduction in size (wound care not reported)53 and in the study with the 7-day screening period, the wound could not decrease by more than 30 percent while treated with saline-moistened gauze.67 None of the three studies reported a wound severity score, but they provided information on wound duration and wound size. A maximum of five applications of Apligraf was available in two studies;63,64 only three applications were permitted in one study.53 One study did not report wound débridement.63 Primary dressings used as control treatments in two studies evaluating diabetic foot ulcers were Mepitel nonadherent dressing53 and saline-moistened Tegapore.67 One study examining venous leg ulcers used Tegapore nonadherent primary dressing gauze bolster as part of compression therapy.63

The fourth study of Apligraf was sponsored by Soluble Systems, the maker of TheraSkin, a cryopreserved, split-thickness, human skin allograft. TheraSkin was compared with Apligraf in a 20-week study.64 This study enrolled 28 patients with 29 diabetic foot ulcers from a large, multisite, podiatric practice. Average wound size was similar between groups (1.89 cm^2^ [Apligraf] vs. 1.82 cm^2^ [TheraSkin]). This study did not report wound duration or presence of screening period before study treatments.

#### Dermagraft

Dermagraft was examined in four studies (3 of diabetic foot ulcers56,62,65 and 1 of venous leg ulcers55). All studies were conducted in multiple settings and were of 12 weeks' duration. The number of patients examined ranged from 50 to 281. Prior to random assignment of subjects, Marston et al.(2003) indicated stratifying patients into two groups based on wound size; however, study results did not reflect these groupings.56 Krishnamoorthy (2003) and Gentzkow (1996) randomly assigned patients to one of three treatment groups and one control group; the three treatment groups varied by number of Dermagraft applications and weeks applied.55,65 Krishnamoorthy (2003) reported on presence of deep vein thrombosis per study group.55 Two of three studies examining diabetic foot ulcers did not report diabetes type.62,65 Three studies excluded patients who responded to usual care during screening periods.55,56,62 In the one study reporting the length of the screening period (14 days), the ulcer could not heal by more than 50 percent while using a multilayered compression bandage.55 The other two studies did not report the length of the screening period and excluded ulcers that increased or decreased in size by more than 50 percent56 or showed rapid healing in response to usual care (compression bandages).62 Multilayered compression therapy was the control treatment in the venous leg ulcer study.55 Standard of care in the three diabetic wound studies consisted of a nonadherent interface plus saline-moistened gauze in two studies; only saline-moistened gauze was used in the third.62

#### Graftjacket

Graftjacket was examined in two studies. One 12-week study enrolled 86 patients from 11 sites.66 Mean wound duration (weeks) was similar (23.3 vs. 22.9); however, the mean wound size was greater in the control group (5.1±4.8 versus 3.6±4.3). Brigido et al. (2006), a 16-week study, enrolled 28 patients at one U.S. site.59 This study reported wound severity (Wagner Grade-2) but did not report wound size or duration.59 Control wound treatments for Graftjacket studies were weekly debridement and Curasol wound hydrogel59 in one study, and one of four moist-wound therapies (i.e., alginates, foams, hydrocolloids, hydrogels) based on level of wound exudate in the other.66 No screening periods to assess wound healing before study treatments were reported in these studies.

#### Oasis

Oasis Wound Matrix was examined in five studies: three studies of venous leg ulcers57,60,69 and two studies of diabetic foot ulcers.54,70 The diabetic foot ulcer studies enrolled 40 and 98 patients. The three studies of venous leg ulcers enrolled between 50 and 120 patients. The studies lasted 8–16 weeks. Two studies were conducted at the same institute.57,60 One study examining venous leg ulcers excluded patients exhibiting greater than 50 percent reduction in surface area during the screening period while being treated with usual care and compression therapy.69 Two studies compared two nongauze wound dressings.54,60 One study (Landsman 2008) randomly assigned patients to Oasis or Dermagraft.54 This 12-week study included a 1-week run-in period prior to random assignment.54 Romanelli (2007) randomly assigned patients to Oasis or Hyaloskin.60 Primary control wound treatments in the remaining studies were described as a petrolatum-impregnated gauze;57 compression therapy consisting of a nonadherent dressing and a four-layer compression bandaging system;69 and a daily application of Regranex Gel.70

#### Hyalograft 3D autograft/Laserskin

Hyalograft 3D impregnated with autologous fibroblasts followed by Laserskin impregnated with autologous keratinocytes was examined in two studies of diabetic foot ulcers and compared with nonadherent paraffin gauze.58,68 One multicenter study enrolled 82 patients from six outpatient centers in Italy; more than 85 percent of the patient population had type 2 diabetes.58 Three patients were excluded after a 15-day run-in period because the ulcer area decreased to less than 1 cm^2^, leaving 79 patients in the intent-to-treat analysis. No significant differences were observed in clinical and wound characteristics; however, mean wound size (dorsal ulcers) was greater for the control group (8.3±9.67 vs. 4.6±5.74). Mean TcPO_2_ [transcutaneous oxygen] was similar in the two groups (>30 mm Hg). The other multicenter study enrolled 180 patients from seven outpatient centers in Italy; 88 percent of the patient population had type 2 diabetes.68 Mean ulcer duration was less than 7 months for the total study population. The two study groups were similar with the exception of ulcer area, which was significantly larger in the treatment group (8.8±9.4 vs. 6.7±7.7; p=0.016). Mean TcPO_2_ [transcutaneous oxygen] was similar between groups, with 25 patients in the treatment group and 29 in the control group with TcPO_2_ of 30 mm Hg or less, at high risk of amputation. This study reported using a 2-week screening period with nonadherent paraffin gauze. Seven patients were later excluded because of having an ulcer area of less than 1 cm^2^; 13 patients did not return after the baseline visit, leaving 160 patients in the intent-to-treat analysis.

#### Talymed (pGlcNAc)

Talymed, a poly-N-acetyl glucosamine (pGlcNAc) containing wound dressing, plus standard of care (n=62) was compared with standard care alone (n=20, Group D) for treating venous leg ulcers in a single, 20-week study.61 The treatment groups were randomized to pGlcNAc once during week 1 (Group A), once every second week (Group B), or once every third week (Group C). Common comorbidities across groups included hypertension (range affected 70 percent to 80 percent), diabetes (54.5 percent to 70.0 percent), class III obesity (range 35 percent to 54 percent), arthritis (30.0 percent to 54.6 percent), and blood clotting disorders (20.0 percent to 40.9 percent). This study did not report using a screening period to assess wound healing before study treatments.

### Efficacy of Skin Substitutes

Only seven of the 57 skin substitute products identified for this report were examined in RCTs.

As mentioned in the previous section, patients were generally excluded from studies if their health was suboptimal, they were taking medication that would interfere with wound healing, their wounds were infected, or the blood flow to the affected area was poor. This restriction means that the outcomes reported in these studies address the efficacy (the capacity to produce a desired effect) of skin substitutes rather than the effectiveness (create an effect in real world practice) of skin substitutes.158 Gartlehner et al. have defined efficacy trials as explanatory trials that “determine whether an intervention produces the expected results under ideal circumstances” and effectiveness trials as pragmatic trials that “measure the degree of beneficial effect under real world clinical settings.”159 Carter et al. have expressed concerns about the applicability of many wound care RCTs to the general population affected by chronic wounds.160

Results from one type of skin substitute cannot be extrapolated to other types because of the different properties and components.10 Neither can results from studies of diabetic foot ulcers be extrapolated to venous leg ulcers because of the differences in etiology and pathophysiology.10 Therefore, clinical evidence from RCTs demonstrating the efficacy of most skin substitutes in treating chronic wounds is not available.

In 12 of the included studies, treatment efficacy was judged by the number of wounds healed after 12 weeks of treatment. Two studies reported on wound healing at less than 12 weeks, one at 8 weeks,57 and one at 11 weeks.58 The remaining studies measured wound healing at 16 weeks,59,60 20 weeks,61 32 weeks,62 and 6 months63 (see Table 49 to Table 53).

Carter158 has emphasized the need to state the “minimal clinical important difference” indicating that the experimental treatment in a wound care study has a clinical benefit over the control treatment. According to Carter, the minimal clinical important difference should be stated for each outcome and the study should be powered to detect this difference. This guards against merely stating that any statistically significant difference is meaningful when the difference is too small to be clinically important. While any significant difference in the number of patients with complete wound healing, wound reoccurrence, infection, or amputation would be clinically important, our examination of the 18 studies included in this report found that no study specifically stated a minimal clinical important difference for these or any other outcomes. Only three studies stated an expected difference between treatment and control outcomes when estimating a study's power and sample size (see Table 32). Edmonds et al.53 expected the treatment to completely heal 50 percent of wounds and the control to heal 32 percent of wounds based on previous pilot studies. Mostow et al.69 expected a 20 percentage point difference and Caravaggi et al.58 expected a 40 percentage point difference.

All studies defined healing as full epithelialization of the wound with no drainage. Based on this outcome, the majority of studies reported significantly more healed wounds in the patients treated with skin substitutes. However, the patients enrolled in these studies were in generally good health and free of infected wounds, medications that would impede wound healing, clinically significant medical conditions, significant peripheral vascular disease, malnutrition, or uncontrolled diabetes. The extent to which these results can be achieved in actual clinical practice is unclear. Other outcomes not directly related to wound healing, such as amputation, hospitalization, return to function, and pain relief, were poorly reported.

#### Apligraf/Graftskin

Apligraf/Graftskin is a living cell, bilayered skin substitute derived from bovine type 1 collagen and human fibroblasts and keratinocytes derived from neonatal foreskins. Based on the percentage of wounds closed at 12 weeks, Apligraf/Graftskin was significantly better in all three studies when compared with usual care (see Table 49).53,63,67 In one of the two studies of diabetic foot ulcers, the control dressings were a nonadherent gauze dressing (Mepitel), covered with a secondary dressing including saline-moistened gauze and dry gauze (healing rate at 12 weeks was 52 percent vs. 26 percent).53 In the other study, the control was saline-moistened, nonadherent gauze (Tegapore) covered with a layer of saline-moistened gauze followed by dry gauze and a layer of petrolatum gauze (healing rate at 12 weeks was 56 percent vs. 38 percent).67 The third study compared Apligraf to Tegapore, a gauze bolster, zinc oxide–impregnated, paste bandage (Unna boot), and self-adherent elastic wrap for treating venous leg ulcers.63 The rate of wounds healed at 6 months was 63 percent for Apligraf and 49 percent for the Unna boot. The median time to wound closure was significantly shorter in the Apligraf group (61 days vs. 181 days).

#### Dermagraft

Dermagraft is a cryopreserved, human fibroblast-derived dermal substitute. The fibroblasts are obtained from human newborn foreskins. Three of the Dermagraft studies examined diabetic foot ulcers using saline-moistened gauze as the control dressing.56,62,65 Marston et al. 2003^56^ reported better healing at 12 weeks in the Dermagraft group and significantly faster time to complete healing. Naughton et al. 1997^62^ reported that more ulcers were healed at 12 weeks in the patients receiving Dermagraft (38.5%) than control (31.7%), but the difference did not reach statistical significance (p=0.14).62 The third study, Gentzkow et al. 1996,^65^ also reported more wounds healed in the Dermagraft group at 12 weeks (50 percent vs. 8 percent). Krishnamoorthy (2003)55 used Dermagraft to treat venous leg ulcers. Both the Dermagraft group and the control group received compression therapy. The number of wounds healed at 12 weeks (38 percent vs. 15 percent) and median time to wound closure (35 weeks vs. 74 weeks) were better in the Dermagraft group (see Table 50).

#### Graftjacket

Graftjacket is processed human dermal matrix used as a skin substitute. The two studies of Graftjacket, both of diabetic foot ulcers, did not use simple gauze dressings as the controls. Reyzelman et al. 2009^66^ used moist-wound therapy alginates, foams, hydrocolloids, or hydrogels as control dressings and Brigido 2006^59^ used Curasol wound hydrogel and weekly debridement as the control. Both studies reported significantly more wounds closed at 12 weeks (70 percent vs. 46 percent compared with the moist-wound therapy dressings and 86 percent vs. 29 percent compared with Curasol). Both studies also reported a reduced time to wound closure in the Graftjacket groups, but the differences were not significantly different (see Table 51).

#### Oasis

Oasis is an extracellular matrix derived from porcine small intestinal submucosa. Among the five RCTs using Oasis, three examined venous leg ulcers. A different control dressing was used in each of the three venous leg ulcer studies: petrolatum-impregnated gauze with no compression, Jaloskin containing the extracellular matrix component hyaluronan, and a nonadherent dressing with compression bandages. Healing rates were better in the Oasis-treated patients (at 8 weeks, 80 percent vs. 65 percent compared with petrolatum-impregnated gauze [p<0.05];57 at 16 weeks, 83 percent vs. 46 percent compared with Jaloskin [p<0.001];60 and at 12 weeks, 55 percent (34/62) vs. 34 percent (20/58) compared with a nonadherent dressing with compression bandages [p=0.02]69). Time to wound closure was significantly better only in the study using a nonadherent dressing with compression bandages. The fourth study of Oasis examined diabetic foot ulcers using Regranex Gel (contains platelet-derived growth factor) as the control. At 12 weeks, the Oasis group had more healed plantar ulcers than the Regranex Gel group (49 percent vs. 28 percent), but the result was not quite statistically significant (p=0.055).70 The fifth study examined treatment of diabetic foot ulcers using Oasis or Dermagraft. At 12 weeks, no significant differences were reported between time to closure (35.67±41.47 days with Oasis vs. 40.90±32.32 days with Dermagraft) or percentage of wound closure (76.9 percent with Oasis vs. 84.6 percent with Dermagraft) (see Table 53).54

#### Hyalograft 3D autograft/Laserskin

Hyalomatrix is a bilayered wound dressing composed of a nonwoven pad made of a benzyl ester of hyaluronic acid (HYAFF) and a semipermeable silicone membrane. In the study by Caravaggi et al. 2003,^58^ Hyalograft 3D impregnated with autologous fibroblasts followed by Laserskin (similar in construction to Hyalomatrix) with autologous keratinocytes were grafted to diabetic foot ulcers. The control treatment was nonadherent paraffin gauze. Laserskin is described under Key Question 1 of this report under the section on biosynthetic products. After 11 weeks, more wounds (dorsal and plantar) were healed in the Hyalograft/Laserskin group than in the control group, but the difference was not statistically significant (65 percent vs. 50 percent). Dorsal ulcer healing was significantly better in the Hyalograft/Laserskin group (67 percent vs. 31 percent) (see Table 52). In the study by Uccioli et al.,68 Hyalograft 3D impregnated with autologous fibroblasts followed by Laserskin with autologous keratinocytes were grafted to diabetic foot ulcers. The difference in complete ulcer healing at 12 weeks was not statistically different for patients in the treatment group (19/80, 24 percent) versus the control group (17/80, 21 percent) (p=0.850). At 20 weeks, complete ulcer healing was achieved in 50 percent of the treatment group and 43 percent of the control group (log-rank test=0.344) (see Table 52).

#### Talymed (pGlcNAc)

Talymed is a sterile wound matrix comprised of shortened fibers of poly-N-acetylglucosamine, isolated from microalgae. In the study by Kelechi et al. 2011,^61^ Talymed plus standard of care was compared to standard care alone for treating venous leg ulcers. Standard care included a nonadherent absorptive primary dressing and a multilayer compression bandage including a zinc oxide impregnated bandage, padding and a self-adherent elastic wrap. After 20 weeks, a statistically significant difference at the p=0.005 level was observed for wounds receiving Talymed plus standard care once every other week versus standard care alone (86.4 percent versus 45 percent, intention to treat analysis with last observation carried forward). More wounds were healed in the Talymed group when applied once every three weeks compared to the control group (65 percent vs. 45 percent), but the difference was not statistically significant. Similar wound healing rates (45 percent) were reported for patients receiving one application of Talymed compared to control.

Table 13 shows the results for complete wound healing at 12 weeks (where possible, or for the closest time point reported) as risk differences and as RR with 95% CI (a RR > 1 indicates that the skin substitute being studied resulted in a higher rate of complet wound healing). Two random effects meta-analyses were possible – one for three studies of Dermagraft and one for two studies of Hyalograft 3D autograft/LaserSkin. The meta-analysis of three studies comparing Dermagraft to saline-moistened gauze showed a summary odds ratio of 1.64 (95% CI 1.10 to 2.43) favoring Dermagraft (Figure 5). The other meta-analysis of two studies comparing Hyalograft 3D autograft/Laserskin to nonadherent paraffin gauze found a summary odds ratio of 1.43 (95% CI 0.80 to 2.54), but this finding was not statistically significant (p=0.22) (Figure 6).

Table 13 Results for complete wound healing

Study | Wound Type | Skin Substitute | Comparison | Number of Patients in Study | Difference in Rate of Wounds Healed (Skin Substitute – Comparator) | p-Value^a^ | Relative Risk for Complete Wound Healing (95% CI) for Skin Substitute vs. Comparator^a^
DiDomenico et al. 2011^64^ | DFU | Apligraf | TheraSkin | 28 | Healed at 12 weeks 41% - 67% = -26% | NS (p=0.21) | 0.66 (0.33 to 1.30)
Landsman et al. 2008^54^ | DFU | Oasis Wound Matrix | Dermagraft | 26 | Healed at 12 weeks 77% - 85% = -8% | NS (p=0.62) | 0.91 (0.62 to 1.33)
Reyzelman et al. 2009^66^ | DFU | Graftjacket acellular matrix | Moist wound therapy with alginates, foams, hydrocolloids, or hydrogels | 85 | Healed at 12 weeks 70% - 46% = 24% | 0.03 | 1.51 (1.02 to 2.22)
Brigido 2006^59^ | DFU | Graftjacket acellular matrix | Weekly debridement, Curasol wound hydrogel and gauze dressing | 28 | Healed at 12 weeks 57% - 7% = 50% | 0.001 | 8.00 (1.15 to 55.80)
Niezgoda et al. 2005^70^ | DFU | Oasis Wound Matrix | Regranex Gel (contains platelet-derived growth factor) | 98 | Healed at 12 weeks 49% - 28% = 21% | NS (p=0.06) | 1.75 (0.94 to 3.26)
Edmonds 2009^53^ | DFU | Apligraf | Nonadherent dressing | 72 | Healed at 12 weeks 52% - 26% = 26% | 0.03 | 1.96 (1.05 to 3.66)
Marston et al. 2003^56^ | DFU | Dermagraft | Saline-moistened gauze | 245 | Healed at 12 weeks 30% - 18% = 12% | 0.03 | 1.64 (1.03 to 2.62)
Naughton et al. 1997^62^ | DFU | Dermagraft | Saline-moistened gauze | 109 | Healed at 12 weeks 39% - 32% = 7% | NS (p=0.28) | 1.21 (0.86 to 1.72)
Gentzkow et al. 1996^65^ | DFU | Dermagraft | Saline-moistened gauze | 50 | Healed at 12 weeks^b^ 30% - 8% = 22% | 0.04 | 1.93 (0.49 to 7.59)
Veves et al. 2001^67^ | DFU | Graftskin | Saline-moistened gauze | 208 | Healed at 12 weeks 56% - 38% = 18% | 0.01 | 1.50 (1.11 to 2.04)
Uccioli et al. 2011^68^ | DFU | Hyalograft 3D autograft/Lasers Skin | Nonadherent paraffin gauze | 160 | Healed at 12 weeks 24% - 21% = 3% | NS (p=0.64) | 1.15 (0.64 to 2.04)
Caravaggi et al. 2003^58^ | DFU | Hyalograft 3D autograft/LaserSkin | Nonadherent paraffin gauze | 79 | Healed at 11 weeks 65% - 50% = 15% | NS (p=0.17) | 1.30 (0.88 to 1.93)
Falanga et al. 1998^63^ | Leg, Venous | Apligraf and elastic compression bandage | Compression therapy with a Unna boot and elastic compression bandage | 275 | Healed at 12 weeks^c^ 53% - 22% = 31% | <0.001^a^ | 2.38 (1.67 to 3.39)
Krishnamoorthy et al. 2003^55^ | Leg, Venous | Dermagraft plus multilayered compression bandage therapy (Profore™) | Multilayered compression therapy | 52 | Healed at 12 weeks 28% - 15% = 13%^c^ | NS (p=0.30)^c^ | 1.83 (0.47 to 7.21)^c^
Romanelli et al. 2010^57^ | Leg, Mixed | Oasis Wound Matrix | Petrolatum-impregnated gauze | 48 | Healed at 8 weeks^d^ 80% - 65% = 15% | NS (p=0.25)^d^ | 1.23 (0.86 to 1.75)
Romanelli et al. 2007^60^ | Leg, Mixed | Oasis Wound Matrix | Hyaloskin (contains hyaluronan) | 54 | Healed at 16 weeks 83% - 46% = 37% | 0.001 | 1.91 (1.16to 3.14)
Mostow et al. 2005^69^ | Leg, Venous | Oasis Wound Matrix with compression | Compression alone | 120 | Healed at 12 weeks 55% - 34% = 21% | 0.022 | 1.59 (1.04 to 2.42)
Kelechi et al. 2011^61^ | Leg, Venous | Talymed poly-N-acetyl glucosamine (pGlcNAc) with compression | Nonadherent absorptive primary dressing with compression | 82 | Healed at 20 weeks^e^ 66% - 45% = 21% | NS (p=0.10) | 1.47 (0.88 to 2.46)^e^

DFU: Diabetic foot ulcer

HYAFF: Benzyl esters of hyaluronic acid

Leg: Vascular leg ulcer

NS: Not Statistically Significant

a Calculated by ECRI Institute; p values are for Risk Difference

b Calculated for all three active groups combined vs. control. A dose-response was noted with more frequent application of Dermagraft associated with higher percentage of patients with complete wound healing.

c Complete healing at 12 weeks calculated from Figure 1 C in Brigido (2006) and from Table 2 and Figure 5 in Falanga (1998)

d The publication states that the p-value for this comparison was “P<0.05”; however we calculate a risk difference of 0.15 (-0.10 to 0.40), p=0.25, a nonsignificant result. The authors state that they used “analysis of variance for multiple comparisons,” but no variables by which the data might have been adjusted are discussed.

e All 3 Talymed groups combined vs. placebo; for groups receiving Talymed every other week to every third week vs. control, the difference was significant at the p=0.016 level, and the relative risk was 1.69 (1.01 to 2.83).

Figure 5 Complete wound healing at 12 weeks with Dermagraft vs. Saline-moistened gauze for diabetic foot ulcers

Figure 5 is a meta-analysis graph depicting the odds ratios for complete wound healing of diabetic foot ulcers at 12 weeks for patients treated with Dermagraft as compared to patients treated with saline-moistened gauze. The included studies were by Marston, Naughton and Gentzkow. The Gentzkow study had 3 Dermagraft-treated groups. The results for all 3 groups were combined for this analysis. The summary result for the three studies examining this comparison indicates that the odds of complete healing were greater for patients treated with Dermagraft than the odds of complete healing in patients treated with saline-moistened gauze. The ratio of the odds was 1.64 (95% CI 1.10 to 2.43).

Figure 6 Complete wound healing at 12 weeks: Hyalograft 3D autograft/LaserSkin vs. nonadherent paraffin gauze for diabetic foot ulcers

Figure 6 is a meta-analysis graph depicting the odds ratios for complete wound healing of diabetic ulcers at 12 weeks for patients treated with Hyalograft 3D autograft/LaserSkin compared to patients treated with nonadherent paraffin gauze. The included studies were by Uccioli and Caravaggi. There were no significant differences in the odds of complete healing with Hyalograft 3D autograft/LaserSkin as compared to treatment with the nonadherent paraffin gauze. The ratio of the odds was 1.43, which might suggest that the Hyalograft 3D autograft/LaserSkin was more effective, but the 95% confidence interval (0.80 to 2.54) includes the possibility of it being less effective than the nonadherent paraffin gauze.

While most studies reported the number of wounds healed at 12 weeks or shorter and a few reported on wound healing at later times, only seven studies reported data on wound recurrence (see Table 54). The rates of recurrence were measured most often over 6 months of follow up. No patterns emerged from the limited data available on this outcome.

### Strength of Evidence

Strength of evidence was evaluated based on risk of bias, consistency, directness, and precision. The strength of evidence assessment is described in Table 14 and Table 15.

Table 14 Key Question 2: Strength of evidence grades for complete wound healing with skin substitutes used to treat diabetic foot ulcers

Comparison | # Studies (Total N) | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Apligraf vs. TheraSkin64 | 1 (28) | MOD | U | D | I % healed at 12 weeks: 41% vs. 67%, NS | ? | INSUFFICIENT
Oasis Wound Matrix vs. Dermagraft54 | 1 (26) | MOD | U | D | I % healed at 12 weeks 77% vs. 85%, NS | ? | INSUFFICIENT
Graftjacket acellular matrix vs. Moist wound therapy66 | 1 (85)^a^ | LOW | U | D | P % healed at 12 weeks: 70% vs. 46%, p=0.03 | Graftjacket | LOW
Graftjacket acellular matrix vs. weekly debridement, Curasol wound hydrogel and gauze dressing59 | 1 (28) | MOD | U | D | P % healed at 12 weeks: 57% vs. 7%, p=0.001 | Graftjacket | INSUFFICIENT
Oasis Wound Matrix vs. Regranex Gel70 | 1 (98) | MOD | U | D | I % healed at 12 weeks: 49% vs. 28%, NS | ? | INSUFFICIENT
Apligraf vs. nonadherent dressing53 | 1 (72)^a^ | LOW | U | D | P % healed at 12 weeks: 52% vs. 26%, p=0.03 | Apligraf | LOW
Dermagraft vs. saline-moistened gauze56,62,65 | 3 (530) | MOD | c | D | P OR 1.64 (95% CI 1.10 to 2.43) | Dermagraft | LOW
Graftskin vs. saline-moistened gauze67 | 1 (208)^a^ | LOW | U | D | P % healed at 12 weeks 56%vs. 38%, p=0.01 | Graftskin | LOW
Hyalograft 3D autograft/LaserSkin vs. nonadherent paraffin gauze58,68 | 2 (239) | LOW | c | D | I OR 1.43 (95% CI 0.80 to 2.54) | ? | INSUFFICIENT

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study. For directness, D = direct and I = indirect.

For precision, I = imprecise, P = precise. For the column labeled “Evidence favors,” ? denotes inconclusive evidence

Other abbreviations: CI = Confidence interval; Diff = difference, N = number of patients, OR = odds ratio, SOE = strength of evidence

a Multicenter study

Table 15 Key Question 2: Strength of evidence grades for complete wound healing with skin substitutes used to treat venous or mixed venous and arterial leg ulcers

Comparison | # Studies (Total N) | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Apligraf and compression vs. compression63 | 1 (275)^b^ | LOW | U | D | P % healed at 12 weeks 53%vs.22%, p<0.001^c^ | Apligraf | LOW
Dermagraft plus multilayered compression bandage therapy vs. multilayered compression bandage therapy55 | 1 (52) | MOD | U | D | I % healed at 12 weeks 38% vs. 15%, NS | ? | INSUFFICIENT
Oasis Wound Matrix with compression vs. compression alone69 | 1 (120)^b^ | LOW | U | D | P % healed at 12 weeks 55% vs. 34%, p=0.02 | Oasis Wound Matrix | LOW
Oasis Wound Matrix vs. a petrolatum-impregnated gauze57,a | 1 48) | MOD | U | D | I % healed at 8 weeks 80% vs. 65%, p=0.25^d^ | ? | INSUFFICIENT
Oasis Wound Matrix vs. Hyaloskin60,a | 1 (54) | MOD | U | D | P % healed at 16 weeks 83% vs. 46%, p=0.001 | Oasis Wound Matrix | INSUFFICIENT
Talymed poly-N-acetyl glucosamine (pGlcNAc) with compression vs. nonadherent absorptive primary dressing with compression61 | 1 (82) | LOW | U | D | I % healed at 20 weeks 66% vs. 45%, NS | ? | INSUFFICIENT

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct and I = indirect.

For precision, I = imprecise, P = precise.

For the column Evidence favors, ? denotes inconclusive evidence

Other abbreviations: NS=nonsignificant

a Mixed venous and arterial ulcers

b Multicenter study

c Complete healing at 12 weeks calculated from Table 2 and Figure 5 in Falanga (1998)

d The publication states that the p-value for this comparison was “P<0.05”; however we calculate a risk difference of 0.15 (-0.10 to 0.40), p=0.25, a nonsignificant result. The authors state that they used “analysis of variance for multiple comparisons,” but no variables by which the data might have been adjusted are discussed.

The strength of the evidence base for evaluating complete wound healing of diabetic foot ulcers at 12 weeks was graded as low for the comparisons of Graftjacket vs. moist wound products,66 the comparison of Apligraf vs. a nonadherent dressing,63 and for Graftskin vs. saline-moistened gauze.67 Each of these studies represented a multicenter trial with a low risk of bias for the outcome of complete wound healing. The outcome measure was direct and the results were precise. Although the evidence for the comparison of Dermagraft vs. saline-moistened gauze came from 3 studies including 530 patients and had a precise result of a direct outcome, we judged the strength of the evidence to be only low because the studies had a moderate risk of bias.56,62,65 The strength of the evidence for other comparisons for diabetic foot ulcers were graded insufficient, primarily because the overall risk of bias was moderate and/or the reported treatment effect (percentage increase in completely healed wounds) was imprecise.

Only two comparisons were judged to have low strength of evidence for complete wound healing of venous or mixed ulcers at 12 weeks. One compared Apligraf and compression to compression,63 and one compared Oasis Wound Matrix with compression to compression.69 In each case, the included study was a multicenter trial, had a low risk of bias and reported a precise and direct result. The other comparisons were from studies with moderate risk of bias and imprecise results; these were judged to have an insufficient strength of evidence grade.

A grade of low means we have low confidence that the evidence reflects the true effect of skin substitutes on complete wound healing, and we believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect. A grade of insufficient indicates that the available evidence does not support a conclusion regarding the comparison. The applicability of the evidence is another important issue with the studies included in this report, and is discussed below.

### Applicability

Applicability of the evidence base depends on how well the included studies examine the patient populations, interventions, comparators, and outcomes of interest to clinical decision makers. When evaluating the patient population, consideration is given to whether patients of interest are included in the studies or whether the eligibility criteria has excluded patients with comorbidities or those in poor health. As mentioned above, no studies in the evidence base examined patients with pressure ulcers, so this evidence base does not provide information on this condition. Also mentioned above was the narrow eligibility criteria that eliminated patients in poor health in most studies. Commonly mentioned reasons for exclusion included the following: infected wounds; use of medications that could impede wound healing; clinically significant medical conditions that could impair wound healing; renal, hepatic, neurologic, or immunologic diseases; significant peripheral vascular disease; malnutrition; and uncontrolled diabetes. This restricts the available evidence to a generally healthy patient group.

No studies of the use of skin substitutes to treat pressure ulcers met our inclusion criteria. Our searches identified only one RCT that compared Dermagraft with usual care in treating stage III pressure ulcers, but this study was excluded because fewer than 50 percent of the enrolled participants contributed data on wound healing. The primary study endpoint was the number of patients with completely healed wounds at 24 weeks with a secondary endpoint of wounds healed at 12 weeks. The study enrolled 34 patients, but by week 12, only 16 patients remained in the study and by week 24 the number of patients was 10. Only two patients in each treatment arm had healed wounds by 24 weeks (see Payne et al. 2004 in Table 20). The lack of studies examining the use of skin substitutes for treating pressure ulcers is puzzling, given that most of the products regulated under the 510(k) process specifically include pressure ulcers as an indication. Publication bias, the failure to publish studies that do not support the efficacy of a new product, may be a possible explanation for the absence of published pressure ulcer studies and could also be present in studies of diabetic foot ulcers and venous leg wounds. Studies may have been conducted but because of poor results compared with usual care, like the Payne et al. study, the study may have been terminated and the results never published. However, our examination of skin substitute studies listed in ClinicalTrials.gov found no completed, terminated, or ongoing studies examining pressure ulcers, indicating that a lack of RCTs in this area may be the explanation.

When considering interventions, only seven of the skin substitutes identified in this report were evaluated in a RCT, meaning that clinical evidence of efficacy from RCTs is not available for the majority of skin substitute products as defined in this report. The skin substitutes derived from human neonatal foreskins and regulated under the PMA process are the best represented group with four studies of Apligraf/Graftskin and four studies of Dermagraft. The animal- or biosynthetic-derived skin substitutes that are regulated under the 510(k) process are represented by five studies of Oasis and one study of Talymed. Two studies of Graftjacket in treating diabetic foot ulcers are the only studies of skin substitutes in the HCT/Ps category.

An evaluation of applicability also considers the comparators and outcomes. In this evidence base, a wide variety of control dressings was used, and in a few of the studies, skin substitute products were actually compared with each other. When considering important wound treatment outcomes, the studies in the evidence base used number of wounds healed in 12 weeks as their primary outcome measure. However, only seven studies reported on wound recurrence, which is another important outcome for determining the efficacy of wound care products.

Taking all these issue of applicability into consideration, overall applicability of the evidence base is limited to a small number of skin substitutes used to treat diabetic foot ulcers and venous leg ulcers, and to patients in generally good health.

## Key Question 3 What type and frequency of adverse events are reported in the clinical literature for each of the FDA-regulated skin substitute products?

Adverse events reported in the included RCTs are listed in Table 55 to Table 59. Cellulitis and osteomyelitis were reported in several studies. Many of the studies report adverse events but do not specify what events occurred.