# References

1 Chern PL, Baum CL, Arpey CJ. Biologic dressings: current applications and limitations in dermatologic surgery. Dermatol Surg. Jun. 2009;35(6):891-906. [pmid: 19397669].
2 Lazarus GS, Cooper DM, Knighton DR, et al. Definitions and guidelines for assessment of wounds and evaluation of healing. Arch Dermatol. Apr. 1994;130(4):489-93. [pmid: 8166487].
3 American Society of Plastic Surgeons. Evidence-based clinical practice guideline: chronic wounds of the lower extremity. Arlington Heights (IL). American Society of Plastic Surgeons. May. 2007:21. Also available: http://www.guideline.gov.
4 Eisenbud D, Huang NF, Luke S, et al. Skin substitutes and wound healing: current status and challenges. Wounds. 2004;16(1):2-17. Also available: http://www.medscape.com/viewarticle/470251_print.
5 Dieckmann C, Renner R, Milkova L, et al. Regenerative medicine in dermatology: biomaterials, tissue engineering, stem cells, gene transfer and beyond. Exp Dermatol. Aug. 2010;19(8):697-706. [pmid: 20545761].
6 Humanitarian device exemption. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA). Aug. 30. 2011 Nov 30. 2010:2. Available: http://www.fda.gov.
7 PMA approvals. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA). Jun. 18. 2011 Nov 30. 2009:3. Available: http://www.fda.gov/MedicalDevices/ProductsandMedicalProcedures/DeviceApprovalsandClearances/PMAApprovals/default.htm.
8 Center for Devices and Radiological Health (CDRH). Premarket notification (510k). [internet]. Silver Spring (MD). U.S. Food and Drug Administration (FDA). Sep. 3. 2011 Nov 30. 2010:4. Available: http://www.fda.gov.
9 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the risk of bias of individual studies in systematic reviews of health care interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. [AHRQ Publication No. 12-EGC047-EF]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Mar. 2012:33. Also available: http://www.effectivehealthcare.ahrq.gov.
10 Center for Biologics Evaluation and Research (CBER). Guidance for industry: chronic cutaneous ulcer and burn wounds — developing products for treatment. Rockville (MD). U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Jun. 2006:22. Also Available: http://www.fda.gov/cder/guidance/index.htm#clinical%20medicine.
11 ACell, Incorporated. 510(k) summary for ACell UBM hydrated wound dressing. K022854. Rockville (MD). U.S. Food and Drug Administration (FDA). Dec. 30. 2002:5. Also Available: http://www.fda.gov.
12 ACell, Incorporated. 510(k) Summary for Acell UBM lyophilized wound dressing. K021637. Rockville (MD). U.S. Food and Drug Administration (FDA). Dec. 19. 2002:5. Also Available: http://www.fda.gov.
13 Aeon Astron Europe B.V. 510(k) summary for Aongen collagen matrix. K080868. Rockville (MD). U.S. Food and Drug Administration (FDA). May. 14. 2009:5. Also Available: http://www.fda.gov.
14 Wright Medical Technology, Inc. 510(k) summary for Atlas wound matrix. K090954. Rockville (MD). U.S. Food and Drug Administration (FDA). Jul. 30. 2009:5. Also Available: http://www.fda.gov.
15 Integra LifeSciences Corporation. 510(k) summary for Avagen wound dressing. K022127. Rockville (MD). U.S. Food and Drug Administration (FDA). Sep. 10. 2002:4. Also Available: http://www.fda.gov.
16 Innocoll Pharmaceuticals. 510(k) summary for collagen sponge. K092805. Rockville (MD). U.S. Food and Drug Administration (FDA). Feb. 16. 2010:5. Also Available: http://www.fda.gov.
17 OASIS Research LLC. 510(k) summary for collagen wound dressing. K002443. Rockville (MD). U.S. Food and Drug Administration (FDA). Oct. 18. 2000:5. Also Available: http://www.fda.gov.
18 Innocoll Pharmaceuticals. 510(k) summary for CollaGUARD. K061746. Rockville (MD). U.S. Food and Drug Administration (FDA). Oct. 2. 2006:5. Also Available: http://www.fda.gov.
19 Hartmann-Conco, Inc. 510(k) summary for CollaSorb collagen wound dressing. K091338. Rockville (MD). U.S. Food and Drug Administration (FDA). Aug. 26. 2009:5. Also Available: http://www.fda.gov.
20 Collamatrix, Inc. 510(k) summary for CollaWound dressing. K061474. Rockville (MD). U.S. Food and Drug Administration (FDA). Jul. 5. 2006:5. Also Available: http://www.fda.gov.
21 Innocoll Pharmaceuticals. 510(k) summary for Collexa. K100574. Rockville (MD). U.S. Food and Drug Administration (FDA). Oct. 4. 2010:5. Also Available: http://www.fda.gov.
22 Innocoll Pharmaceuticals. 510(k) summary for Collieva. K081782. Rockville (MD). U.S. Food and Drug Administration (FDA). Sep. 30. 2008:5. Also Available: http://www.fda.gov.
23 Coreleader Biotech Co., Ltd. 510(k) summary for Coreleader Colla-Pad. K102946. Rockville (MD). U.S. Food and Drug Administration (FDA). May. 20. 2011:5. Also Available: http://www.fda.gov.
24 Pegasus Biologics, Inc. 510(k) summary for DermADAPT wound dressing. K061494. Rockville (MD). U.S. Food and Drug Administration (FDA). Sep. 21. 2006:5. Also Available: http://www.fda.gov.
25 TEI Biosciences, Inc. 510(k) summary for DressSkin. K023778. Rockville (MD). U.S. Food and Drug Administration (FDA). Sep. 29. 2003:5. Also Available: http://www.fda.gov.
26 Brennen Medical, Inc. 510(k) summary E-Z Derm biosynthetic wound dressing. K935189. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA). Jul. 11. 2011 Nov 30. 1994:1. Available: http://www.fda.gov.
27 Mesynthes, Ltd. 510(k) summary for Endoform dermal template. K092096. Rockville (MD). U.S. Food and Drug Administration (FDA). Jul. 10. 2009:5. Also Available: http://www.fda.gov.
28 Tissue Repair Company. 510(k) summary for Excellagen. K110318. Rockville (MD). U.S. Food and Drug Administration (FDA). Oct. 3. 2011:6. Also Available: http://www.fda.gov.
29 Organogenesis, Inc. 510(k) summary for FortaDerm wound dressing. K011026. Rockville (MD). U.S. Food and Drug Administration (FDA). Jun. 13. 2001:4. Also Available: http://www.fda.gov.
30 ConvaTec, a division of E.R. Squibb and Sons, Inc. 510(k) summary of safety and effectiveness for HA absorbent wound dressing. K984388. Rockville (MD). U.S. Food and Drug Administration (FDA). Mar. 3. 1999:5. Available: http://www.fda.gov.
31 ENCOLL Corp. 510(k) summary for Helicoll. K040314. Rockville (MD). U.S. Food and Drug Administration (FDA). Aug. 12. 2004:6. Also Available: http://www.fda.gov.
32 Integra LifeSciences Corporation. 510(k) summary for bilayer matrix wound dressing. K021792. Rockville (MD). U.S. Food and Drug Administration (FDA). Aug. 14. 2002:4. Available: http://www.fda.gov.
33 Integra LifeSciences Corporation. 510(k) summary for Integra flowable wound matrix. K072113. Rockville (MD). U.S. Food and Drug Administration (FDA). Oct. 10. 2007:4. Also Available: http://www.fda.gov.
34 LifeCell Corporation. 510(k) summary for LTM wound dressing. K082103. Rockville (MD). U.S. Food and Drug Administration (FDA). Oct. 8. 2008:6. Also Available: http://www.fda.gov.
35 ACell, Inc. 510(k) summary for ACell MatriStem wound sheet. K092926. Rockville (MD). U.S. Food and Drug Administration (FDA). Oct. 28. 2009:4. Available: http://www.fda.gov.
36 ACell. 510(k) summary for MatriStem wound matrix. K112409. Rockville (MD). U.S. Food and Drug Administration (FDA). Aug. 29. 2011:4. Also Available: http://www.fda.gov.
37 Collagen Matrix, Inc. 510(k) summary for collagen topical wound dressing. K040558. Rockville (MD). U.S. Food and Drug Administration (FDA). Mar. 17. 2004:5. Also Available: http://www.fda.gov.
38 Melkerson MN. (Director, Division of General, Restorative and Neurological Devices, Office of Device Evaluation, Center for Devices and Radiological Health, U.S. Food and Drug Administration). Section 510(k) premarket notification of intent to market Medline collagen wound dressing. Medline Industries, Inc. K060456. 2006. Jun. 19. 3 p.
39 Cook Biotech, Inc. Special 510(k) summary for Oasis wound matrix. K061711. Rockville (MD). U.S. Food and Drug Administration (FDA). Jul. 18. 2006:4. Available: http://www.fda.gov.
40 TEI Biosciences, Inc. 510(k) summary for PriMatrix. K083440. Rockville (MD). U.S. Food and Drug Administration (FDA). Dec. 12. 2008:5. Also Available: http://www.fda.gov.
41 TEI Biosciences, Inc. 510(k) summary for PriMatrix. K061407. Rockville (MD). U.S. Food and Drug Administration (FDA). Jun. 29. 2006:5. Available: http://www.fda.gov.
42 Cook Biotech, Incorporated. 510(k) summary for SIS Wound Dressing II. K993948. Rockville (MD). U.S. Food and Drug Administration (FDA). Jan. 6. 2000:4. Also Available: http://www.fda.gov.
43 Cook Biotech Incorporated. 510(k) Summary for SS Matrix. K020732. Rockville (MD). U.S. Food and Drug Administration (FDA). May. 30. 2002:4. Also Available: http://www.fda.gov.
44 Southwest Technologies, Inc. 510(k) summary for Stimulen collagen. K030774. Rockville (MD). U.S. Food and Drug Administration (FDA). Aug. 9. 2004:5. Also Available: http://www.fda.gov.
45 Sewon Cellontech Co., Ltd. 510(k) summary for TheraForm standard/sheet. K090812. Rockville (MD). U.S. Food and Drug Administration (FDA). Jul. 30. 2009:5. Also Available: http://www.fda.gov.
46 Synovis Orthopedic and Woundcare, Inc. 510(k) summary for Unite Biomatrix. K112399. Rockville (MD). U.S. Food and Drug Administration (FDA). Sep. 7. 2011:5. Also Available: http://www.fda.gov.
47 Pegasus Biologics, Inc. 510(k) summary for Unite Biomatrix. K071425. Rockville (MD). U.S. Food and Drug Administration (FDA). Jun. 20. 2007:5. Also Available: http://www.fda.gov.
48 Fidia Advanced Biopolymers. 510(k) summary for Hyalomatrix KD wound dressing. K001508. Rockville (MD). U.S. Food and Drug Administration (FDA). Apr. 23. 2001:4. Available: http://www.fda.gov.
49 Anika therapeutics, S.r.l. 510(k) summary for Hyalomatrix. K073251. Rockville (MD). U.S. Food and Drug Administration (FDA). May. 19. 2011:5. Also Available: http://www.fda.gov.
50 Fidia Advanced Biopolymers S.r.l. 510(k) summary for Jaloskin. K001508. Rockville (MD). U.S. Food and Drug Administration (FDA). Jan. 26. 2010:5. Also Available: http://www.fda.gov.
51 PolyMedics Innovations, GmbH. 510(k) summary for suprathel wound and burn dressing. K090160. Rockville (MD). U.S. Food and Drug Administration (FDA). May. 7. 2009:6. Also Available: http://www.fda.gov.
52 Marine Polymer Technologies, Inc. 510(k) summary for Talymed. K102002. Rockville (MD). U.S. Food and Drug Administration (FDA). Jul. 28. 2010:5. Also Available: http://www.fda.gov.
53 Edmonds M, European and Australian Apligraf Diabetic Foot Ulcer Study Group. Apligraf in the treatment of neuropathic diabetic foot ulcers. Int J Low Extrem Wounds. Mar. 2009;8(1):11-8. [pmid: 19189997].
54 Landsman A, Roukis TS, DeFronzo DJ, et al. Living cells or collagen matrix: which is more beneficial in the treatment of diabetic foot ulcers?. Wounds. 2008;20(5):111-6.
55 Krishnamoorthy L, Harding K, Griffiths D, et al. The clinical and histological effects of Dermagraft in the healing of chronic venous leg ulcers. Phlebology. 2003;18(1):12-22.
56 Marston WA, Hanft J, Norwood P, et al. The efficacy and safety of Dermagraft in improving the healing of chronic diabetic foot ulcers: results of a prospective randomized trial. Diabetes Care. Jun. 2003;26(6):1701-5. [pmid: 12766097].
57 Romanelli M, Dini V, Bertone MS. Randomized comparison of OASIS wound matrix versus moist wound dressing in the treatment of difficult-to-heal wounds of mixed arterial/venous etiology. Adv Skin Wound Care. Jan. 2010;23(1):34-8. [pmid: 20101114].
58 Caravaggi C, De Giglio R, Pritelli C, et al. HYAFF 11-based autologous dermal and epidermal grafts in the treatment of noninfected diabetic plantar and dorsal foot ulcers: a prospective, multicenter, controlled, randomized clinical trial. Diabetes Care. Oct. 1. 2003;26(10):2853-9. [pmid: 14514591].
59 Brigido SA. The use of an acellular dermal regenerative tissue matrix in the treatment of lower extremity wounds: a prospective 16-week pilot study. Int Wound J. Sep. 2006;3(3):181-7. [pmid: 16984575].
60 Romanelli M, Dini V, Bertone M, et al. OASIS wound matrix versus Hyaloskin in the treatment of difficult-to-heal wounds of mixed arterial/venous aetiology. Int Wound J. Mar. 2007;4(1):3-7. [pmid: 17425543].
61 Kelechi TJ, Mueller M, Hankin CS, et al. A randomized, investigator-blinded, controlled pilot study to evaluate the safety and efficacy of a poly-N-acetyl glucosamine-derived membrane material in patients with venous leg ulcers. J Am Acad Dermatol. Jun. 2012;66(6):e209-15. Epub 2011 May 26. [pmid: 21620515].
62 Naughton G, Mansbridge J, Gentzkow G. A metabolically active human dermal replacement for the treatment of diabetic foot ulcers. Artif Organs. Nov. 1997;21(11):1203-10. [pmid: 9384327].
63 Falanga V, Margolis D, Alvarez O, et al. Rapid healing of venous ulcers and lack of clinical rejection with an allogeneic cultured human skin equivalent. Human skin equivalent investigators group. Arch Dermatol. Mar. 1998;134(3):293-300. [pmid: 9521027].
64 DiDomenico L, Emch KJ, Landsman AR, et al. A prospective comparison of diabetic foot ulcers treated with either cryopreserved skin allograft or bioengineered skin substitute. Wounds. 2011;23(7):184-9. Also available: http://cwccl.patientadvocate.org/articles/DiDomenico%20et%20al.%20Wounds.pdf.
65 Gentzkow GD, Iwasaki SD, Hershon KS, et al. Use of dermagraft, a cultured human dermis, to treat diabetic foot ulcers. Diabetes Care. Apr. 1996;19(4):350-4. [pmid: 8729158].
66 Reyzelman A, Crews RT, Moore JC, et al. Clinical effectiveness of an acellular dermal regenerative tissue matrix compared to standard wound management in healing diabetic foot ulcers: a prospective, randomised, multicentre study. Int Wound J. Jun. 2009;6(3):196-208. [pmid: 19368581].
67 Veves A, Falanga V, Armstrong DG, et al. Graftskin, a human skin equivalent, is effective in the management of noninfected neuropathic diabetic foot ulcers: a prospective randomized multicenter clinical trial. Diabetes Care. Feb. 2001;24(2):290-5. [pmid: 11213881].
68 Uccioli L, Giurato L, Ruotolo V, et al. Two-step autologous grafting using HYAFF scaffolds in treating difficult diabetic foot ulcers: results of a multicenter, randomized controlled clinical trial with long-term follow-up. Int J Low Extrem Wounds. Jun. 2011;10(2):80-5. [pmid: 21693443].
69 Mostow EN, Haraway GD, Dalsing M, et al. Effectiveness of an extracellular matrix graft (OASIS Wound Matrix) in the treatment of chronic leg ulcers: a randomized clinical trial. J Vasc Surg. May. 2005;41(5):837-43. [pmid: 15886669].
70 Niezgoda JA, Van Gils CC, Frykberg RG, et al. Randomized clinical trial comparing OASIS Wound Matrix to Regranex Gel for diabetic ulcers. Adv Skin Wound Care. Jun. 2005;18(5 Pt 1):258-66. [pmid: 15942317].
71 Laing P. Diabetic foot ulcers. Am J Surg. Jan. 1994;167(1A):31S-6S. [pmid: 8109682].
72 Frykberg RG, Armstrong DG, Giurini J, et al. Diabetic foot disorders: a clinical practice guideline. American College of Foot and Ankle Surgeons. J Foot Ankle Surg. 2000;39(5 Suppl):S1-60. [pmid: 11280471].
73 Lavery LA, Armstrong DG, Harkless LB. Classification of diabetic foot wounds. [internet]. North Miami Beach (FL). Wound Care Institute. 1991. 2005 Sep 7. 11 p. Available: http://www.woundcare.org/newsvol2n2/ulcer2.htm.
74 Stadelmann WK, Digenis AG, Tobin GR. Physiology and healing dynamics of chronic cutaneous wounds. Am J Surg. Aug. 1998;176(2A Suppl):26S-38S. [pmid: 9777970].
75 Stillman RM. Diabetic ulcers. [internet]. Omaha (NE). eMedicine.com. 2005. Mar. 22. 2005 Sep 7. 25 p. Available: http://www.emedicine.com/med/topic551.htm.
76 de Leon J. Negative pressure wound therapy in pressure ulcer management. Ostomy Wound Manage. Feb. 2005;51(2A Suppl):3-8. [pmid: 15699557].
77 Folkedahl BA, Frantz R. Treatment of pressure ulcers. Iowa City (IA). University of Iowa Gerontological Nursing Interventions Research Center, Research Dissemination Core. 2002. Aug. 30 p.
78 Gupta S, Baharestani M, Baranoski S, et al. Guidelines for managing pressure ulcers with negative pressure wound therapy. Adv Skin Wound Care. Nov-Dec. 2004;17(Suppl 2):1-16. [pmid: 15716646].
79 Smith DM. Pressure ulcers in the nursing home. Ann Intern Med. Sep. 15. 1995;123(6):433-42. [pmid: 7639444].
80 Sieggreen MY, Kline RA. Recognizing and managing venous leg ulcers. Adv Skin Wound Care. Jul-Aug. 2004;17(6):302-11. quiz 312-3. [pmid: 15289718].
81 Moffatt CJ, Dorman MC. Recurrence of leg ulcers within a community ulcer service. J Wound Care. Feb. 1995;4(2):57-61. [pmid: 7600337].
82 Barr DM. The Unna's boot as a treatment for venous ulcers. Nurse Pract. Jul. 1996;21(7):55-6. 61. 4. 71. 2. passim. [pmid: 8823788].
83 Goodfield M. Optimal management of chronic leg ulcers in the elderly. Drugs Aging. May. 1997;10(5):341-8. [pmid: 9143855].
84 Falanga V, Eaglstein WH. A therapeutic approach to venous ulcers. J Am Acad Dermatol. May. 1986;14(5 Pt 1):777-84. [pmid: 3519695].
85 O'Meara S, Cullum NA, Nelson EA. Compression for venous leg ulcers (Review). Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2009;(1). 2009 May 15. [Art. No.: CD000265]. Available:. [doi: 10.1002/14651858.CD000265.pub2].
86 Gist S, Tio-Matos I, Falzgraf S, et al. Wound care in the geriatric client. Clin Interv Aging. 2009;4:269-87. [pmid: 19554098].
87 Nelson EA, Bradley MD. Dressings and topical agents for arterial leg ulcers. Cochrane Database Syst Rev. 2007;(1). CD001836. [pmid: 17253465].
88 de la Torre JI, Chambers JA. Wound healing, chronic wounds. [internet]. Omaha (NE). eMedicine.com. 2008. Oct. 9. 2009 May 5. 13 p. Available: http://emedicine.medscape.com/article/1298452-print.
89 Stillman RM. Wound care. [internet]. Omaha (NE). eMedicine.com. 2008. Aug. 19. 2009 May 18. 28 p. Available: http://emedicine.medscape.com/article/194018-print.
90 Brett D. A review of collagen and collagen-based wound dressings. [internet]. St. Petersburg (FL). Smith & Nephew Inc. 2008. Dec. 12. 3 p. Available: http://www.woundsresearch.com/.
91 Hanna JR, Giacopelli JA. A review of wound healing and wound dressing products. J Foot Ankle Surg. Jan-Feb. 1997;36(1):2-14. discussion 79. [pmid: 9031020].
92 Schultz GS, Davidson JM, Kirsner RS, et al. Dynamic reciprocity in the wound microenvironment. Wound Repair Regen. Mar-Apr. 2011;19(2):134-48. [pmid: 21362080].
93 Krafts KP. Tissue repair: the hidden drama. Organogenesis. Oct-Dec. 2010;6(4):225-33. [pmid: 21220961].
94 Gabriel A. Wound healing and growth factors. Medscape Reference. [internet]. New York (NY). WebMD LLC. 2011. Aug. 22. 2012 Mar 22. 7 p. Available: http://emedicine.medscape.com/article/1298196-overview#showall.
95 Lau J, Tatsioni A, Balk E, et al. Usual care in the management of chronic wounds: a review of the recent literature. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2005. Mar. 8. 53 p.
96 Ovington LG. Hanging wet-to-dry dressings out to dry. Adv Wound Care. Mar-Apr. 2002;15(2):79-86.
97 ECRI Institute. Occlusive dressings for the treatment of chronic wounds. Plymouth Meeting (PA). ECRI Institute. 2000. Feb. 141 p. (Technology Assessment Report).
98 Jones JE, Nelson EA. Skin grafting for venous leg ulcers. Cochrane Database Syst Rev. 2007;(2). CD001737. [pmid: 17443510].
99 Ovington LG. Advances in wound dressings. Clin Dermatol. Jan-Feb. 2007;25(1):33-8. [pmid: 17276199].
100 Ovington LG. The well-dressed wound: an overview of dressing types. Wounds. Jan-Feb. 1998;10(Suppl A):1A-9A.
101 Kannon GA, Garrett AB. Moist wound healing with occlusive dressings a clinical review. Dermatol Surg. Jul. 1995;21(7):583-90. [pmid: 7606367].
102 Jones V, Grey JE, Harding KG. Wound dressings. BMJ. Apr. 1. 2006;332(7544):777-80. [pmid: 16575081].
103 Hansson C. Interactive wound dressings a practical guide to their use in older patients. Drugs Aging. Oct. 1997;11(4):271-84. [pmid: 9342557].
104 Papanas N, Maltezos E. Becaplermin gel in the treatment of diabetic neuropathic foot ulcers. Clin Interv Aging. 2008;3(2):233-40. [pmid: 18686746].
105 CFR - Code of Federal Regulations Title 21: Subchapter L--regulations under certain other acts administered by the Food and Drug Administration, Sec. 1271. Human cells, tissues, and cellular and tissue-based products. Silver Spring (MD). U.S. Food and Drug Administration (FDA). 2010. Apr. 1. 35 p.
106 Gottrup F, Apelqvist J, Price P, et al. Outcomes in controlled and comparative studies on non-healing wounds: recommendations to improve the quality of evidence in wound management. J Wound Care. Jun. 2010;19(6):237-68. [pmid: 20551864].
107 Gottrup F, Apelqvist J. Present and new techniques and devices in the treatment of DFU: a critical review of evidence. Diabetes Metab Res Rev. Feb. Suppl 1. 2012;28:64-71. [pmid: 22271726].
108 Serena T, Bates-Jensen B, Carter MJ, et al. Consensus principles for wound care research obtained using a Delphi process. Wound Repair Regen. May-Jun. 2012;20(3):284-93. [pmid: 22564224].
109 Narine L, Yee DS, Einarson TR, et al. Quality of abstracts of original research articles in CMAJ in 1989. CMAJ. Feb. 15. 1991;144(4):449-53. [pmid: 1993292].
110 Pitkin RM, Branagan MA, Burmeister LF. Accuracy of data in abstracts of published research articles. JAMA. Mar. 24-31. 1999;281(12):1110-1. [pmid: 10188662].
111 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
112 Higgins JP, Green S, editors. Cochrane handbook for systematic reviews of interventions version 5.1.0. The Cochrane Collaboration. 2011. Mar. Also available: http://www.cochrane-handbook.org/.
113 Sonnad SS, Goldsack J, Mohr P, et al. Methodological recommendations for comparative effectiveness research on the treatment of chronic wounds. Version 2.0 Final. Baltimore (MD). Center for Medical Technology Policy. 2012. Oct. 1. 57 p.
114 Schulz KF, Chalmers I, Altman DG. The landscape and lexicon of blinding in randomized trials. Ann Intern Med. Feb. 5. 2002;136(3):254-9. [pmid: 11827510].
115 Mayrovitz HN, Soontupe LB. Wound areas by computerized planimetry of digital images: accuracy and reliability. Adv Skin Wound Care. May. 2009;22(5):222-9. [pmid: 19521289].
116 Laplaud AL, Blaizot X, Gaillard C, et al. Wound debridement: comparative reliability of three methods for measuring fibrin percentage in chronic wounds. Wound Repair Regen. Jan-Feb. 2010;18(1):13-20. [pmid: 20082676].
117 Rogers LC, Bevilacqua NJ, Armstrong DG, et al. Digital planimetry results in more accurate wound measurements: a comparison to standard ruler measurements. J Diabetes Sci Technol. Jul. 2010;4(4):799-802. [pmid: 20663440].
118 Oien RF, Hakansson A, Hansen BU, et al. Measuring the size of ulcers by planimetry: a useful method in the clinical setting. J Wound Care. May. 2002;11(5):165-8. [pmid: 12055939].
119 Little C, McDonald J, Jenkins MG, et al. An overview of techniques used to measure wound area and volume. J Wound Care. Jun. 2009;18(6):250-3. [pmid: 19661849].
120 AlloDerm regenerative tissue matrix. [internet]. Branchburg (NJ). LifeCell Corporation. 2011. 2011 Nov 3. 1 p. Available: http://www.lifecell.com/alloderm-regenerative-tissue-matrix/95/.
121 Allopatch HD: acellular human dermis. [internet]. Edison (NJ). MTF Sports Medicine. 2011 Nov 3. 1 p. Available: http://mtfsports.org/allopatch_hd.html.
122 Allograft catalog. Centennial (CO). AlloSource. 2011. Mar. 32 p. Also Available: http://www.allosource.org/content/pdf/allografts/allografts.pdf.
123 Cymetra micronized alloderm tissue. [internet]. Branchburg (NJ). LifeCell Corporation. 2011. 2011 Nov 3. 1 p. Available: http://www.lifecell.com/cymetra-micronized-alloderm-tissue/.
124 Skin and Wound Allograft Institute (SWAI) - dermacell. [internet]. Virginia Beach (VA). LifeNet Health. 2011 Nov 3. 2 p. Available: http://www.accesslifenethealth.org/application/skin-and-wound-allograft-institute.
125 FlexHD. [internet]. Edison (NJ). Musculoskeletal Transplant Foundation. 2011 Nov 3. 1 p. Available: http://www.mtf.org/professional/flex_hd.html.
126 FlexHD acellular hydrated dermis family. [internet]. West Somerville (NJ). Ethicon, Inc. 2011 Nov 3. 1 p. Available: http://www.ethicon360.com/products/flex-hd-acelular-hydrated-dermis-family.
127 GammaGraft. [internet]. Pittsburgh (PA). Promethean LifeSciences, Inc. 2011 Nov 3. 2 p. Available: http://pl-s.com/gammagraft.html.
128 GraftJacket regenerative tissue matrix - ulcer repair. San Antonio (TX). Kinetic Concepts, Inc. 10 p. Also available: http://www.kci1.com/cs/Satellite?blobcol=urldata&blobheadername1=Content-type&blobheadername2=Content-disposition&blobheadername3=MDT-Type&blobheadervalue1=application%2Fpdf&blobheadervalue2=inline%3B+filename%3D184%252F69%252FGRAFTJACKET%25C2%25AE%2.
129 Matrix HD. [internet]. Alachua (FL). RTI Biologics, Inc. 2011 Nov 3. 3 p. Available: http://www.rtix.com/surgeons/implants/sports-medicine/matrix-hd.
130 MemoDerm. [internet]. Memphis (TN). Memometal, Inc. 2011 Nov 3. 2 p. Available: http://www.mmi-usa.com/memoderm/index.html.
131 Puros dermis allograft tissue matrix. The natural choice for soft tissue augmentation. [internet]. Carlsbad (CA). Zimmer Dental, Inc. 2011 Nov 3. 3 p. Available: http://www.zimmerdental.com/eblast/september06Dermis.htm.
132 Repliform tissue regeneration matrix. [internet]. Natick (MA). Boston Scientific Corporation. 2011 Nov 3. 2 p. Available: http://www.bostonscientific.com/Device.bsci?page=HCP_Overview&navRelId=1000.1003&method=DevDetailHCP&id=10005411&pageDisclaimer=Disclaimer.ProductPage (http://www.bostonscientific.com/Device.bsci?page=HCP_Overview&navRelId=1000.1003&method=DevDetailHCP=id=10005411&pageDisclaimer=Disclaimer.ProductPage).
133 TheraSkin. [internet]. Newport News (VA). Soluble Systems. 2011 Nov 3. 2 p. Available: http://www.solublesystems.com/Theraskin.
134 What is Apligraf?. [internet]. Canton (MA). Organogenesis Inc. 2011 Nov 3. 1 p. Available: http://www.apligraf.com/professional/what_is_apligraf/index.html.
135 U.S. Food and Drug Administration (FDA). Approval of the premarket approval application (PMA) for Apligraf. P950032. 1998. May. 22. 8 p. Also Available: http://www.fda.gov.
136 Dermagraft. [internet]. La Jolla (CA). Advanced Biohealing, Inc. 2011 Nov 3. 2 p. Available: http://www.dermagraft.com/about/overview/.
137 U.S. Food and Drug Administration (FDA). Approval of the premarket approval application (PMA) for Dermagraft. P000036. 2000. Sep. 28. 7 p. Also Available: http://www.fda.gov.
138 Endoform platform. [internet]. Lower Hutt (New Zealand). Mesynthes, Ltd. 2011 Nov 3. 2 p. Available: http://www.mesynthes.com/index.php?option=com_content&view=category&layout=blog&id=15&Itemid=17.
139 E-Z Derm: biosynthetic wound dressing. [internet]. Geneva (Switzerland). AM Scientifics, Ltd. 2011 Nov 3. 3 p. Available: http://www.am-scientifics.com/?id=18.
140 Integra product description and benefits. [internet]. Plainsboro (NJ). Integra LifeSciences Corporation. 2011 Nov 3. 2 p. Available: http://www.ilstraining.com/bmwd/bmwd/bmwd_it_01.html.
141 MatriStem wound care matrix. [internet]. Columbia (MD). ACell, Inc. 2011 Nov 3. 1 p. Available: http://www.acell.com/wound_care.php.
142 Oasis wound matrix. [internet]. Healthpoint Biotherapeutics. 2011 Nov 3. 1 p. Available: http://www.oasiswoundmatrix.com/home.
143 PriMatrix. [internet]. Boston. TEI Biosciences. 2011 Nov 3. 1 p. Available: http://www.teibio.com/PriMatrix.aspx.
144 Hyalomatrix. [internet]. Bedford (MA). Anika Therapeutics, Inc. 2011 Nov 3. 1 p. Available: http://www.anikatherapeutics.com/products/dermal/hyalomatrix.html.
145 Suprathel. [internet]. Denkendorf (Germany). PolyMedics Innovations GmbH. 2011 Nov 3. 1 p. Available: http://www.suprathel.de/?L=1.
146 Advanced BioHealing Inc. An initial evaluation of the safety and activity of celaderm treatment regimens in healing venous leg ulcers. ClinicalTrials.gov [database online]. Bethesda (MD). National Library of Medicine (U.S.). 2000. 2011 Nov 3. 4 p. Available: http://clinicaltrials.gov/ct2/show/NCT00399308 NLM Identifier: NCT00399308.
147 Laboratories Genevrier. Efficacy and safety study of dermagen vs conventional treatment to treat diabetic neuropathic foot ulcer. ClinicalTrials.gov [database online]. Bethesda (MD). National Library of Medicine. 2000. 2011 Nov 3. 4 p. Available: http://www.clinicaltrials.gov/ct2/show/NCT00521937 NLM Identifier: NCT00521937.
148 Epicel - severe burn treatment. [internet]. Cambridge (MA). Genzyme Corporation. 2011 Nov 3. 1 p. Available: http://www.genzyme.com/business/biosurgery/burn/burn_home.asp.
149 U.S. Food and Drug Administration (FDA). Approval of the humanitarian device exemption (HDE) application for the Genzyme Biosurgery Epicel. H990002. 2007. Oct. 25. 8 p. Also Available: http://www.fda.gov.
150 EpiDex. [internet]. Leipzig (Germany). Euroderm AG. 2011 Nov 3. 1 p. Available: http://www.euroderm-biotech.de/.
151 Matriderm. [internet]. Billerbeck (Germany). Dr. Suwelack Skin & Health Care AG. 2011 Nov 3. 2 p. Available: http://www.skin-healthcare.de/en/tissue_regeneration/MATRIDERM_profil.php.
152 What is OrCel - product description. [internet]. Englewood (CA). Forticell Bioscience, Inc. 2011 Nov 3. 1 p. Available: http://www.forticellbioscience.com/orcel.html.
153 U.S. Food and Drug Administration (FDA). Approval of the humanitarian device exemption (HDE) application for composite cultured skin. H990013. 2001. Feb. 21. 8 p. Also Available: http://www.fda.gov.
154 About PermaDerm. [internet]. Little Falls (NJ). Regenicin, Inc. 2011 Nov 3. 1 p. Available: http://www.regenicin.com/about/about-permaderm.html.
155 StrataGraft skin substitute. [internet]. Madison (WI). Stratatech Corporation. 2011 Nov 3. 2 p. Available: http://www.stratatechcorp.com/about/index.php.
156 Xelma - extracellular matrix protein. [internet]. Gothenburg (Sweden). Molnlycke Health Care. 2011 Nov 3. 2 p. Available: http://www.molnlycke.com/com/Wound-Care-Products/Product-selector---Wound-division/Tabs/Products/Xelma/?activeTab=2.
157 Marston W. (Professor and Chief, Division of Vascular Surgery, Medical Director, UNC Wound Healing Center, University of North Carolina School of Medicine). Personal communication. 2012. Jan. 20. 4 p.
158 Carter MJ. Evidence-based medicine: an overview of key concepts. Ostomy Wound Manage. Apr. 1. 2010;56(4):68-85. [pmid: 20424294].
159 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol. Oct. 2006;59(10):1040-8. [pmid: 16980143].
160 Carter MJ, Fife CE, Walker D, et al. Estimating the applicability of wound care randomized controlled trials to general wound-care populations by estimating the percentage of individuals excluded from a typical wound-care population in such trials. Adv Skin Wound Care. Jul. 2009;22(7):316-24. [pmid: 20375969].
161 Falanga V, Sabolinski M. A bilayered living skin construct (APLIGRAF) accelerates complete closure of hard-to-heal venous ulcers. Wound Repair Regen. Jul-Aug. 1999;7(4):201-7. [pmid: 10781211].
162 Steinberg JS, Edmonds M, Hurley DP Jr, et al. Confirmatory data from EU study supports Apligraf for the treatment of neuropathic diabetic foot ulcers. J Am Podiatr Med Assoc. Jan-Feb. 2010;100(1):73-7. [pmid: 20093548].
163 Teng YJ, Li YP, Wang JW, et al. Bioengineered skin in diabetic foot ulcers. Diabetes Obes Metab. Apr. 2010;12(4):307-15. [pmid: 20380651].
164 Gibbs S, Blok C, Hoogenband HM, et al. Autologous cultured skin, Tiscover for ambulant treatment of hard-to-heal leg ulcers: a revolutionary approach. Wound Repair Regen. Jul-Aug. 2009;17(4):A57.
165 Langer A, Rogowski W. Systematic review of economic evaluations of human cell-derived wound care products for the treatment of venous leg and diabetic foot ulcers. BMC Health Serv Res. 2009;9:115. [pmid: 19591680].
166 Barber C, Watt A, Pham C, et al. Influence of bioengineered skin substitutes on diabetic foot ulcer and venous leg ulcer outcomes. J Wound Care. Dec. 2008;17(12):517-27. [pmid: 19052516].
167 Blozik E, Scherer M. Skin replacement therapies for diabetic foot ulcers: systematic review and meta-analysis. Diabetes Care. Apr. 2008;31(4):693-4. [pmid: 18162495].
168 Cardinal M, Eisenbud DE, Phillips T, et al. Early healing rates and wound area measurements are reliable predictors of later complete wound closure. Wound Repair Regen. Jan. 2008;16(1):19-22. [pmid: 18211575].
169 Chow I, Lemos EV, Einarson TR. Management and prevention of diabetic foot ulcers and infections: a health economic review. Pharmacoeconomics. 2008;26(12):1019-35. [pmid: 19014203].
170 Vowden P, Romanelli M, Price P. Effect of amelogenin extracellular matrix protein and compression on hard-to-heal venous leg ulcers. J Wound Care. May. 2007;16(5):189-95. [pmid: 17552400].
171 O'Donnell TF Jr, Lau J. A systematic review of randomized controlled trials of wound dressings for chronic venous ulcer. J Vasc Surg. Nov. 2006;44(5):1118-25. [pmid: 17098555].
172 Brigido SA, Boc SF, Lopez RC. Effective management of major lower extremity wounds using an acellular regenerative tissue matrix: a pilot study. Orthopedics. Jan. 2004;27(1 Suppl):s145-9. [pmid: 14763548].
173 Ehrlich HP. Understanding experimental biology of skin equivalent: from laboratory to clinical use in patients with burns and chronic wounds. Am J Surg. May. 2004;187(5A):29S-33S. [pmid: 15147989].
174 Payne WG, Wright TE, Ochs D, et al. An exploratory study of dermal replacement therapy in the treatment of stage III pressure ulcers. J Appl Res. 2004;4(1):12-23.
175 Tausche AK, Skaria M, Bohlen L, et al. An autologous epidermal equivalent tissue-engineered from follicular outer root sheath keratinocytes is as effective as split-thickness skin autograft in recalcitrant vascular leg ulcers. Wound Repair Regen. Jul-Aug. 2003;11(4):248-52. [pmid: 12846911].
176 Hanft JR, Surprenant MS. Healing of chronic foot ulcers in diabetic patients treated with a human fibroblast-derived dermis. J Foot Ankle Surg. Sep-Oct. 2002;41(5):291-9. [pmid: 12400712].
177 Falanga VJ. Tissue engineering in wound repair. Adv Skin Wound Care. May-Jun. 2000;13(2 Suppl):15-9. [pmid: 11074998].
178 Harding K, Cutting K, Price P. The cost-effectiveness of wound management protocols of care. Br J Nurs. Nov. 8. 2000;9(19 Suppl):S6-24. [pmid: 12271239].
179 Warriner RA 3rd, Cardinal M. on behalf of the TIDE Investigators. Human fibroblast-derived dermal substitute: results from a treatment investigational device exemption (TIDE) study in diabetic foot ulcers. Adv Skin Wound Care. Jul. 2011;24(7):306-11. [pmid: 21685733].
180 Landsman AS, Cook J, Cook E, et al. A retrospective clinical study of 188 consecutive patients to examine the effectiveness of a biologically active cryopreserved human skin allograft (TheraSkin) on the treatment of diabetic foot ulcers and venous leg ulcers. Foot Ankle Spec. Feb. 2011;4(1):29-41. [pmid: 21135263].
181 Romanelli M, Kaha E, Stege H, et al. Effect of amelogenin extracellular matrix protein and compression on hard-to-heal venous leg ulcers: follow-up data. J Wound Care. Jan. 2008;17(1):17-8. [pmid: 18210952].
182 Romanelli M, Dini V, Vowden P, et al. Amelogenin, an extracellular matrix protein, in the treatment of venous leg ulcers and other hard-to-heal wounds: experimental and clinical evidence. Clin Interv Aging. 2008;3(2):263-72. [pmid: 18686749].
183 Hu S, Kirsner RS, Falanga V, et al. Evaluation of Apligraf persistence and basement membrane restoration in donor site wounds: a pilot study. Wound Repair Regen. Jul-Aug. 2006;14(4):427-33. [pmid: 16939570].
184 Vowden P, Romanelli M, Peter R, et al. The effect of amelogenins (Xelma) on hard-to-heal venous leg ulcers. Wound Repair Regen. May-Jun. 2006;14(3):240-6. [pmid: 16808801].
185 Chester DL, Balderson DS, Papini RP. A review of keratinocyte delivery to the wound bed. J Burn Care Rehabil. May. 2004;25(3):266-75. [pmid: 15273468].
186 Jeschke MG, Rose C, Angele P, et al. Development of new reconstructive techniques: use of Integra in combination with fibrin glue and negative-pressure therapy for reconstruction of acute and chronic wounds. Plast Reconstr Surg. Feb. 2004;113(2):525-30. [pmid: 14758212].
187 Omar AA, Mavor AI, Jones AM, et al. Treatment of venous leg ulcers with Dermagraft. Eur J Vasc Endovasc Surg. Jun. 2004;27(6):666-72. [pmid: 15121121].
188 Saap LJ, Donohue K, Falanga V. Clinical classification of bioengineered skin use and its correlation with healing of diabetic and venous ulcers. Dermatol Surg. Aug. 2004;30(8):1095-100. [pmid: 15274699].
189 Sams HH, Chen J, King LE. Graftskin treatment of difficult to heal diabetic foot ulcers: one center's experience. Dermatol Surg. Aug. 2002;28(8):698-703. [pmid: 12174061].
190 Bass MJ, Phillips LG. Pressure sores. Curr Probl Surg. Feb. 2007;44(2):101-43. [pmid: 17386304].
191 Grey JE, Lowe G, Bale S, et al. The use of cultured dermis in the treatment of diabetic foot ulcers. J Wound Care. Jul. 1998;7(7):324-5. [pmid: 9791355].
192 Fivenson D, Scherschun L. Clinical and economic impact of Apligraf for the treatment of nonhealing venous leg ulcers. Int J Dermatol. Dec. 2003;42(12):960-5. [pmid: 14636194].
193 Kirsner RS, Fastenau J, Falabella A, et al. Clinical and economic outcomes with graftskin for hard-to-heal venous leg ulcers: a single-center experience. Dermatol Surg. Jan. 2002;28(1):81-2. [pmid: 11991277].
194 Brem H, Balledux J, Sukkarieh T, et al. Healing of venous ulcers of long duration with a bilayered living skin substitute: results from a general surgery and dermatology department. Dermatol Surg. Nov. 2001;27(11):915-9. [pmid: 11737123].
195 Dougherty EJ. An evidence-based model comparing the cost-effectiveness of platelet-rich plasma gel to alternative therapies for patients with nonhealing diabetic foot ulcers. Adv Skin Wound Care. Dec. 2008;21(12):568-75. [pmid: 19065083].
196 Karr JC. Retrospective comparison of diabetic foot ulcer and venous stasis ulcer healing outcome between a dermal repair scaffold (PriMatrix) and a bilayered living cell therapy (Apligraf). Adv Skin Wound Care. Mar. 2011;24(3):119-25. [pmid: 21326023].
197 Ortega-Zilic N, Hunziker T, Lauchli S, et al. EpiDex Swiss field trial 2004-2008. Dermatology. 2010;221(4):365-72. [pmid: 21071921].
198 Mizuno H, Miyamoto M, Shimamoto M, et al. Therapeutic angiogenesis by autologous bone marrow cell implantation together with allogeneic cultured dermal substitute for intractable ulcers in critical limb ischaemia. J Plast Reconstr Aesthet Surg. Nov. 2010;63(11):1875-82. [pmid: 20060793].
199 Kirsner RS, Warriner R, Michela M, et al. Advanced biological therapies for diabetic foot ulcers. Arch Dermatol. Aug. 2010;146(8):857-62. [pmid: 20713816].
200 Clerici G, Caminiti M, Curci V, et al. The use of a dermal substitute to preserve maximal foot length in diabetic foot wounds with tendon and bone exposure following urgent surgical debridement for acute infection. Int Wound J. Jun. 2010;7(3):176-83. [pmid: 20602648].
201 Chen X, Chen H, Zhang G. Management of wounds with exposed bone structures using an artificial dermis and skin grafting technique. J Plast Reconstr Aesthet Surg. Jun. 2010;63(6):e512-8. [pmid: 20004631].
202 Brigido SA, Schwartz E, McCarroll R, et al. Use of an acellular flowable dermal replacement scaffold on lower extremity sinus tract wounds: a retrospective series. Foot Ankle Spec. Apr. 2009;2(2):67-72. [pmid: 19825754].
203 Han SK, Kim HS, Kim WK. Efficacy and safety of fresh fibroblast allografts in the treatment of diabetic foot ulcers. Dermatol Surg. Sep. 2009;35(9):1342-8. [pmid: 19500128].
204 Renner R, Harth W, Simon JC. Transplantation of chronic wounds with epidermal sheets derived from autologous hair follicles--the Leipzig experience. Int Wound J. Jun. 2009;6(3):226-32. [pmid: 19538195].
205 Ramelet AA, Hirt-Burri N, Raffoul W, et al. Chronic wound healing by fetal cell therapy may be explained by differential gene profiling observed in fetal versus old skin cells. Exp Gerontol. Mar. 2009;44(3):208-18. [pmid: 19049860].
206 Canonico S, Campitiello F, Della Corte A, et al. The use of a dermal substitute and thin skin grafts in the cure of “complex” leg ulcers. Dermatol Surg. Feb. 2009;35(2):195-200. [pmid: 19215255].
207 Vriens AP, Waaijman T, van den Hoogenband HM, et al. Comparison of autologous full-thickness gingiva and skin substitutes for wound healing. Cell Transplant. 2008;17(10-11):1199-209. [pmid: 19181214].
208 Winters CL, Brigido SA, Liden BA, et al. A multicenter study involving the use of a human acellular dermal regenerative tissue matrix for the treatment of diabetic lower extremity wounds. Adv Skin Wound Care. Aug. 2008;21(8):375-81. [pmid: 18679086].
209 Nie X, Cai JK, Yang HM, et al. Successful application of tissue-engineered skin to refractory ulcers. Clin Exp Dermatol. Nov. 2007;32(6):699-701. [pmid: 17725663].
210 Mermet I, Pottier N, Sainthillier JM, et al. Use of amniotic membrane transplantation in the treatment of venous leg ulcers. Wound Repair Regen. Jul-Aug. 2007;15(4):459-64. [pmid: 17650088].
211 Yonezawa M, Tanizaki H, Inoguchi N, et al. Clinical study with allogeneic cultured dermal substitutes for chronic leg ulcers. Int J Dermatol. Jan. 2007;46(1):36-42. [pmid: 17214717].
212 Gibbs S, van den Hoogenband HM, Kirtschig G, et al. Autologous full-thickness skin substitute for healing chronic wounds. Br J Dermatol. Aug. 2006;155(2):267-74. [pmid: 16882162].
213 Martin BR, Sangalang M, Wu S, et al. Outcomes of allogenic acellular matrix therapy in treatment of diabetic foot wounds: an initial experience. Int Wound J. Jun. 2005;2(2):161-5. [pmid: 16722865].
214 Moustafa M, Simpson C, Glover M, et al. A new autologous keratinocyte dressing treatment for non-healing diabetic neuropathic foot ulcers. Diabet Med. Jul. 2004;21(7):786-9. [pmid: 15209775].
215 Redekop WK, McDonnell J, Verboom P, et al. The cost effectiveness of Apligraf treatment of diabetic foot ulcers. Pharmacoeconomics. 2003;21(16):1171-83. [pmid: 14594438].
216 Phillips TJ, Manzoor J, Rojas A, et al. The longevity of a bilayered skin substitute after application to venous ulcers. Arch Dermatol. Aug. 2002;138(8):1079-81. [pmid: 12164746].
217 Browne AC, Vearncombe M, Sibbald RG. High bacterial load in asymptomatic diabetic patients with neurotrophic ulcers retards wound healing after application of Dermagraft. Ostomy Wound Manage. Oct. 2001;47(10):44-9. [pmid: 11890078].
218 Sibbald RG, Torrance GW, Walker V, et al. Cost-effectiveness of Apligraf in the treatment of venous leg ulcers. Ostomy Wound Manage. Aug. 2001;47(8):36-46. [pmid: 11890002].
219 Yamaguchi Y, Kubo T, Tarutani M, et al. Epithelial-mesenchymal interactions in wounds: treatment of palmoplantar wounds by nonpalmoplantar pure epidermal sheet grafts. Arch Dermatol. May. 2001;137(5):621-8. [pmid: 11346340].
220 Falabella AF, Valencia IC, Eaglstein WH, et al. Tissue-engineered skin (Apligraf) in the healing of patients with epidermolysis bullosa wounds. Arch Dermatol. Oct. 2000;136(10):1225-30. [pmid: 11030768].
221 Brem H, Balledux J, Bloom T, et al. Healing of diabetic foot ulcers and pressure ulcers with human skin equivalent: a new paradigm in wound healing. Arch Surg. Jun. 2000;135(6):627-34. [pmid: 10843357].
222 Monami M, Vivarelli M, Desideri CM, et al. Autologous skin fibroblast and keratinocyte grafts in the treatment of chronic foot ulcers in aging type 2 diabetic patients. J Am Podiatr Med Assoc. Jan-Feb. 2011;101(1):55-8. [pmid: 21242471].
223 Kerstein MD, Brem H, Giovino KB, et al. Development of a severity scale for evaluating the need for Graftskin in nonhealing venous ulcers. Adv Skin Wound Care. Mar-Apr. 2002;15(2):66-71. [pmid: 11984049].
224 Sopata M, Luczak J, Ciupinska M. Effect of bacteriological status on pressure ulcer healing in patients with advanced cancer. J Wound Care. Mar. 2002;11(3):107-10. [pmid: 11933727].
225 Chockalingam N, Ashford RL, Dunning D. The influence of four wound dressings on the kinetics of human walking. J Wound Care. Oct. 2001;10(9):371-4. [pmid: 12964282].
226 Micallef L, Lebreton C, Bordeau N, et al. Evaluation of human bone marrow-derived mesenchymal stem cell capacities to support epidermis development in a skin substitute. Comparative study with human dermal fibroblasts. Wound Repair Regen. Nov-Dec. 2010;18(6):A88.
227 Tauzin H, Rolin G, Viennet C, et al. Development of a skin substitute for therapeutic use, based on human amnion. J Invest Dermatol. Sep. 2009;129:S20.
228 Upton Z, Shooter G, Van Lonkhuyzen D, et al. Positive clinical results with vitronectin: IGF complexes for the treatment of chronic wounds. Growth Horm IGF Res. 2010;20:S68-9.
229 Tang J, Guo WC, Yu L, et al. Clinical efficacy of artificial skin combined with vacuum sealing drainage in treating large-area skin defects. Chin J Traumatol. Oct. 2010;13(5):289-92. [pmid: 20880455].
230 Faulhaber J, Felcht M, Teerling G, et al. Long-term results after reconstruction of full thickness scalp defects with a dermal regeneration template. J Eur Acad Dermatol Venereol. May. 2010;24(5):572-7. [pmid: 19888947].
231 Hiles M, Nihsen E, Hodde J. Biologics in fistula surgery: parallels with chronic wounds. Semin Colon Rectal Surg. Mar. 2009;20(1):32-7.
232 Huldt-Nystrom T, Meuleneire F, Acton C. Xelma, an advanced wound treatment for venous ulcers: a European perspective. Wounds UK. Mar. 2008;4(1):84-8.
233 Russo G, Crippa M, Lorenzi G, et al. Bioengineered skin grafts after revascularization in the treatment of ischemic ulcers. Chirurgia. Aug. 2006;19(4):253-6.
234 Boyce ST. Fabrication, quality assurance, and assessment of cultured skin substitutes for treatment of skin wounds. Biochem Eng J. Aug. 15. 2004;20(2-3):107-12.
235 Eming SA, Smola H, Krieg T. Treatment of chronic wounds: state of the art and future concepts. Cells Tissues Organs. 2002;172(2):105-17. [pmid: 12426487].
236 Cavorsi JP. Venous ulcers of the lower extremities: current and newer management techniques. Top Geriatr Rehabil. 2000;16(2):24-34.
237 Moneta GL, Falanga V, Altman MI, et al. Nonoperative management of venous leg ulcers: evolving role of skin substitutes. Vasc Surg. Mar. 1999;33(2):197-210.
238 Shaikh FM, Giri SK, Durrani S, et al. Experience with porcine acellular dermal collagen implant in one-stage tension-free reconstruction of acute and chronic abdominal wall defects. World J Surg. Oct. 2007;31(10):1966-72. [pmid: 17661188].