# Ongoing Clinical Trials

Our search of ClinicalTrials.gov identified 17 clinical trials with the following status: completed (8), currently recruiting (7), not yet open (1) and unknown (1). Of the eight completed trials, publications were not found for five trials. These trials were completed in 2003 (1), 2008 (1), 2011 (2) and 2012 (1) (see Table 16).

Table 16 Clinical trials

Clinicaltrials.gov Identifier or Other Identifier | Sponsor | Purpose | Start Date | Expected Completion Date | Estimated Enrollment | Status | Publications
NCT01676272 | Soluble Systems, LLC | To compare a bioengineered skin substitute to a human skin allograft | July 2012 | April 2013 | 100 | Enrolling by invitation only | N/A
NCT01619670 | University Hospital, Basel, Switzerland | To evaluate Apligraf in nonhealing wounds of patients with epidermolysis bullosa | June 2012 | June 2014 | 18 | Currently recruiting | N/A
NCT01729286 | TEI Biosciences Inc. | To assess lower extremity diabetic (healed) ulcers with PriMatrix | September 2012 | September 2014 | 224 | Currently recruiting | N/A
NCT01612806 | TEI Biosciences Inc. | To assess PriMatrix and PriMatrix Ag for the treatment of venous leg ulcers | June 2011 | Not reported | 90 | Currently recruiting | N/A
NCT01623882 | Spiracur, Inc. | To assess use of Apligraf and SNaP Pressure Wound Therapy System to treat diabetic and venous stasis lower extremity ulcers | June 2012 | December 2015 | 60 | Not yet open | N/A
NCT00521937 | Laboratoires Genévrier | To evaluate the healing properties of Dermagen® for treating DFUs. | January 2009 | December 2010 | 388 | Unknown | N/A
NCT00909870 | Advanced Biohealing, Inc. | Patients with venous leg ulcers will be randomly assigned to receive standard therapy (compression) alone or compression plus Dermagraft(R). | May 2009 | September 2011 | 500 | Completed August 2011 | None provided
NCT01270633 | TEI Biosciences | To compare the clinical and economic effectiveness of PriMatrix and SOC in treating DFUs in subjects with controlled DM and without significantly compromised arterial circulation. | December 2010 | September 2012 | 25 | Completed | None provided
NCT01327937 | Organogenesis | To use microarray technology to identify and characterize the gene expression of multiple relevant genes in biopsies of nonhealing venous ulcers. | March 2011 | June 2013 | 30 | Currently recruiting | N/A
NCT01060670 | LifeSciences Corp. | To evaluate the safety and effectiveness of the Integra^®^ Dermal Regeneration Template for treating DFUs located distal to the malleolus in subjects with DM; neuropathy, and without significantly compromised arterial circulation | April 2010 | October 2013 | 350 | Currently recruiting | N/A
NCT01450943 | VA Northern California Health Care System | The primary objective of this study is to assess the effectiveness of cellular dermal replacement tissue vs. nonviable extracellular matrix (ECM) for treating nonhealing DFUs. Our hypothesis is that these devices are of equal efficacy. | October 2011 | October 2014 | 171 | Currently recruiting | N/A
NCT00399308 | Advanced Biohealing, Inc. | This pilot study was designed to test the safety of Celaderm(TM) in treating venous leg ulcers and to give preliminary information about the efficacy of two different Celaderm(TM) dosing regimens. | January 2007 | April 2008 | 40 | Completed | None provided
NCT01181453 | Advanced Biohealing, Inc. | This study randomly assigns patients with DFUs to receive standard therapy (surgical débridement, saline moistened gauze and offloading) alone or standard therapy plus Dermagraft(R). Dermagraft is a device containing live human fibroblasts grown on an absorbable Vicryl mesh. | December 1998 | March 2000 | 314 | Completed | 1 Marston et al.56 included in report
NCT01181440 | Advanced Biohealing, Inc. | Patients with plantar DFUs will be randomized to receive conventional therapy (débridement, infection control, saline-moistened gauze dressings, and standardized off-weighting) alone or conventional therapy plus Dermagraft(R). | September 1994 | January 1997 | 281 | Completed | 2
NCT00007280 | National Institute of Arthritis and Musculoskeletal and Skin Diseases | To evaluate whether a graft of bioengineered skin (BSC), (Apligraf), stimulates the healing process in a person's own skin at the edge of a wound (known as the edge effect). | October 2000 | August 2005 | 50 | Completed | 11 Falanga 1999^161^ excluded as subgroup analysis of prior published study (Falanga 1998^63^ included); remaining publications were narrative reviews or cell-based studies
NCT01353495 | Wright Medical Technology | Have indolent diabetic ulcers completely healed by the Acellular Porcine Dermal Matrix (APM) in 12 weeks. | April 2010 | April 2011 | 40 | Completed | None provided
NCT00270946 | Ortec International | To evaluate the clinical benefits and safety of OrCel plus compression therapy (SOC) vs. compression therapy in treating venous ulcers. | April 2002 | December 2003 | 130 | Completed | None provided

N/A: Not applicable