# Methods

The Center for Medicare Management of the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: ECRI Institute EPC (Contract Number: HHSA 290-2007-10063). The purpose of this review is to provide information to CMS for consideration in HCPCS coding decisions. The review will facilitate CMS' evaluation of HCPCS coding for skin substitutes by providing CMS with relevant studies and information for consideration of coding changes.

AHRQ's EPC Program partners with private and public organizations to perform scientific reviews of a variety of topics. The process of systematic review as practiced by the EPC Program follows specific prescribed steps:

1. The investigators start with formulated “key” questions. These questions test hypotheses and are structured using the PICO framework: patients, intervention of interest, comparator, and outcomes. EPCs are encouraged to focus on outcomes that are relevant and important to patients (patient-oriented outcomes). The framework is depicted visually in the “analytic framework” that the EPC program uses to show the relationship between the key questions and the outcomes used to address these questions. (See Figure 3.)
2. Inclusion and exclusion criteria for studies to be used in the review are determined based on the specific key questions. Criteria may vary for each question in the review.
3. Next, an objective and comprehensive search of the medical literature and gray literature, (i.e., reports, monographs and studies produced by government agencies, educational facilities and corporations that do not appear in the peer-reviewed literature) is conducted. The reference lists of included studies are examined for any studies not identified by electronic searches.
4. Studies are compared with the inclusion criteria developed before examining the evidence, and those included in the review are then critically appraised, noting features of the design and conduct of the studies that create potential for bias. Risk of bias, in this context, is the extent to which the design and conduct of a single study “protect against all bias in the estimate of treatment effect.”9 Studies with a low potential for bias are typically described as being of “high quality,” whereas those with high potential for bias are described as being of “low” or “poor” quality, and those of moderate quality as having intermediate potential for bias. The degree to which a study protects against bias is referred to as “internal validity.” Following this appraisal, data are extracted from the included studies and analyzed or summarized as appropriate.

Figure 3 Analytic framework

Figure 3 is an analytic framework that depicts the events that patients undergoing treatment for chronic wounds may experience. The framework includes from left to right the patient population of interest, treatment comparisons, patient-oriented outcomes and adverse effects that may occur from treatment. In the first frame, we have our patient population of interest, “patients with a chronic wound.” For this report, only adults with chronic wounds will be included. An arrow leads the patient to treatments by either skin substitutes or other wound treatments. Next, the path leads to a third frame, the patient-oriented outcomes. First, we list percentage of completely closed/healed wounds. Listed below in separate boxes are additional patient-oriented outcomes of interest: time to complete wound closure, wound reoccurrence, wound infection, need for amputation, need for hospitalization, return to baseline activities of daily living and function, pain reduction, exudate and odor reduction. Lastly, an arrow connects all treatments to the topic of adverse effects which may occur due to treatment.

The following is a detailed explanation of the methods followed in this review.

## Key Questions

1. What are the U.S. Food and Drug Administration (FDA)-regulated skin substitutes that fall under each of the following pathways: PMA, 510(k), PHS 361[21 CFR 1270 & 1271]?
  a. PMA: Premarket approval by FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices. Class III devices support or sustain human life, are of substantial importance in preventing impairment of human health, or present a potential, unreasonable risk of illness or injury.
  b. 510(k): A 510(k) is a premarketing submission made to FDA to demonstrate that the device to be marketed is as safe and effective, that is, substantially equivalent, to a legally marketed device that is not subject to PMA.
  c. PHS 361 [21 CFR 1270 & 1271]: Human cells, tissues, and cellular and tissue-based products. Creates a unified registration and listing system for establishments that manufacture HCT/Ps and establishes donor eligibility, current good tissue practice, and other procedures to prevent the introduction, transmission, and spread of communicable diseases by HCT/Ps.
2. For patients with chronic wounds (pressure ulcers, diabetic foot ulcers, venous leg ulcers, or arterial leg ulcers), are skin substitutes more effective than other wound care options (usual or standard care, or usual or standard care plus synthetic dressings, growth factors, skin grafts, or other treatments used as a comparison) in promoting wound healing for the following outcome measures:
  a. Percentage of completely closed/healed wounds (skin closure with complete re-epithelialization without drainage or dressing requirements)
  b. Time to complete wound closure
  c. Wound reoccurrence
  d. Wound infection
  e. Need for amputation
  f. Need for hospitalization (frequency and duration)
  g. Return to baseline activities of daily living and function
  h. Pain reduction
  i. Exudate and odor reduction
3. What type and frequency of adverse events are reported in the clinical literature for each of the FDA-regulated skin substitute products?

## Analytic Framework

The analytic framework below (Figure 3) graphically depicts the events that individuals with chronic wounds experience as they are treated with a skin substitute. This figure portrays the pathway of events that patients experience, starting from when they are first identified (the far left of the figure), to the treatments they receive, and to patient-oriented outcomes. As such, patients in the population of interest are identified and “enter” the pathway at the left of the figure. Key Questions 2 and 3 are represented in the framework by a circled number. Key Question 1 is not related to treatment and outcomes and is not depicted in the figure.

According to a guidance document prepared by FDA in 2006, clinical outcomes associated with the use of a wound-treatment product or device can be broadly grouped into two categories—improved wound healing and improved wound care.10 A number of outcomes or endpoints fall into these two categories. According to the FDA document, “complete wound closure of a chronic nonhealing wound is one of the most objective and clinically meaningful wound healing endpoints” and “complete wound closure is defined as skin reepithelialization without drainage or dressing requirements at two consecutive study visits 2 weeks apart.”10 Wound closure as an outcome measure has also been emphasized in several other wound care publications.2,106,107 We therefore selected complete wound healing as the primary patient-centered outcome for this report. We did not require that studies report confirmation of wound closure at two consecutive visits 2 weeks apart for inclusion in this report but tabled information on wound reassessment along with other study design and conduct information in Table 27 to Table 31. A single assessment of wound closure at a single followup period would only allow for determination of minimal healing as described by Lazarus et al.2 We are therefore also interested in noting how many studies used reassessment of wound closure and at what time periods.

FDA regards the parameter of partial wound healing as insufficient as a primary endpoint “because the clinical benefit of incremental wound size changes has not been established.”10 We therefore did not consider this a primary outcome for this report.

Improvements in wound care can potentially reduce the occurrence of conditions, such as infection, that can interfere with proper wound healing.10 Thus, measuring the impact of skin substitutes on the occurrence or healing of infections, as well as its impact on the incidence of other problems, such as sepsis, edema, or amputation, is important.

## Inclusion Criteria

We used the following criteria to determine which studies identified by our searches would be included in our analysis. These criteria were developed before any review of the clinical literature. Inclusion and exclusion criteria were developed to specify the types of studies appropriate for addressing Key Questions 2 and 3.

### Population

1. Study must have enrolled human subjects in whom a chronic wound (pressure ulcer, diabetic foot ulcer, venous leg ulcer, or arterial leg ulcer) lasting more than 30 days without healing has been diagnosed.
  Studies of animals are outside the scope of this assessment.
2. Results for patients with different wound etiologies (diabetic ulcers, pressure wounds, leg ulcers) must be reported separately.
  Percentage healed, time to heal, and the frequency and characteristics of adverse events can be expected to vary depending on the underlying cause of the wound.

### Intervention

3 Study must evaluate the efficacy of a commercially available skin substitute product regulated by FDA.

### Study Design

4 Studies must be RCTs.
  Systematically reviewing all of the clinical research for all of these products is beyond the scope of this report. We sought to determine the number of RCTs examining these products and to assess the efficacy of skin substitutes under the conditions examined in these trials. Properly conducted RCTs are considered the best study design for determining the actual efficacy of a medical intervention. The Panel On Wound Care Evidence-based Research (POWER) has suggested that RCTs are the preferred approach for studying biologically based products because these products “are likely to need more sophisticated study designs for acceptability because of issues of unpredictability, possibility of adverse events, and demonstration of efficacy under controlled situations.”108
5 Studies must have enrolled at least 10 patients per study arm.
  The results of smaller studies and especially case reports are often not applicable to the general population.

### Outcomes

6 Study must have reported on at least one of the outcomes listed in Key Question 2.
7 The reliability and validity of all instruments measuring relevant outcomes, such as activities of daily and function or pain, must have been addressed in the published literature.
  However, if a study did not use a validated instrument, the entire study was not necessarily excluded for all outcomes—only its data from instruments in which the psychometric properties were not reported in the published literature were excluded.
8 For all outcomes, we considered only time points for which at least 50 percent of the enrolled participants contributed data.

### Publication Type

9 Study must have been published in English.
  Although we recognize that in some situations exclusion of non-English studies could lead to bias, we believe that the few instances in which this may occur do not justify the time and cost typically necessary for translation of studies to identify those of acceptable quality for inclusion in our review.
10 Study was reported as a full-length, peer-reviewed article.
  Published abstracts and letters alone do not include sufficient details about experimental methods to permit verification and evaluation of study design.109,110
11 When several sequential reports from the same study center were available, we included outcome data from only the largest, most recent or most complete report.
  However, we used relevant data from earlier and smaller reports if the report presented pertinent data not presented in the larger, more recent report. This criterion prevents double-counting of patients.

Table 20 in Appendix A lists the reasons for exclusion for all excluded studies and retrieved documents.

## Search Strategy

To identify relevant information on the benefits and harms of skin substitutes, we employed the following search strategies:

- Systematic search of 13 external and internal electronic databases, including CINAHL, Embase, and Medline from 1950 (Medline)/1980 (Embase)/1982 (CINAHL) to the present for fully published, primary, clinical studies. A detailed search strategy and a full explanation of our electronic database search are presented in Appendix A.
- Systematic search of the following databases unlimited by date for secondary publications (e.g., systematic reviews, Health Technology Assessments): The Cochrane Database of Systematic Reviews (Cochrane Reviews), Database of Abstracts of Reviews of Effects (DARE), and Health Technology Assessment and Database (HTA).
- Search for additional published and unpublished studies, which included the following steps:
  ○ Manual search of bibliographies listed in fully published studies
  ○ Search and written inquiry to regulatory agencies, including FDA and CMS
  ○ Search of www.ClinicalTrials.gov and www.controlled-trials.com for ongoing clinical trials
- Publications were also suggested for inclusion by individuals who commented on the draft report.

Figure 4 is an attrition diagram that provides a visualization of the disposition of materials as they were evaluated for possible inclusion in the report.

Figure 4 Disposition of documents identified by searches

Figure 4 is an attrition diagram that depicts the status of documents identified by internal literature searches. The diagram begins with a box outlining the 95 citations identified. Several boxes ensue which are connected by arrows going from top to bottom which follow the citations as they are being screened for possible inclusion in the report. In the first frame we remove articles at the abstract level that are not relevant to the report. 60 citations were excluded. The path then follows the 35 full articles retrieved. During this phase of screening we do a more extensive screening of the articles based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. 20 articles were excluded during this evaluation phase. Three studies were added after comments were reviewed leaving 18 articles that met our inclusion criteria.

The most common reasons for exclusion of retrieved articles (see Table 20) were the following:

- Study was not a randomized controlled trial.
- Product is not commercially available in the United States.
- Study was a narrative review.
- Publication duplicated an already included study.

Identified articles excluded at the abstract level are listed in Table 21.

## Study Risk-of-Bias Assessment

After determining which of the publications identified in our searches met our inclusion criteria, we assessed the potential for bias in these studies. Judging study quality by assessing the potential for bias is the first part of grading the strength of an evidence base according to the system used by the EPC program and detailed in the publication by Viswanathan et al.9 In this system, the risk-of-bias assessment tool is a set of questions that explicitly evaluates the risk of bias. The questions are geared specifically for the field of research being assessed in the review. The potential for bias in each study included in this report was assessed using a risk-of-bias assessment instrument developed by ECRI Institute based on the criteria described by Viswanathan et al.9 and modified specifically for comparative studies of wound care interventions.

Viswanathan et al.9 consider “risk of bias to refer to the extent to which a single study's design and conduct protect against all bias in the estimate of effect.” Bias is systematic error–as opposed to random error–introduced into a study that leads to an underestimation or an overestimation of the true effect of an intervention.111,112 In well-constructed studies, biases are minimized by appropriate study design and conduct, and changes in outcomes and differences in outcomes between groups are definitively attributed to the treatment of interest. For these reasons, high-quality studies are those in which study design and conduct eliminate or greatly reduce the potential for bias. The degree to which a study protects against bias is referred to as “internal validity.”

The potential for bias in any study may be assessed by asking specific questions about the design and conduct of the study that limits the potential for selection, performance, attrition, and detection biases.9 Selection bias refers to “systematic differences between baseline characteristics of the groups that arise from self-selection of treatments, physician-directed selection of treatments, or association of treatment assignments with demographic, clinical, or social characteristics.”9 Proper randomization and concealment of allocation are intended to limit selection bias. Performance bias refers to “systematic differences in the care provided to participants and protocol deviation.”9 Differences in care include use of the experimental intervention in the control group and unbalanced use of additional interventions. Attrition bias refers to “systematic differences in the loss of participants from the study and how they were accounted for in the results (e.g., incomplete followup, differential attrition).”9 Patients who drop out of a study or are lost to followup may be “systematically different from those who remain in the study”9 and the even distribution of baseline characteristics that was achieved through randomization may be lost if attrition is different between experimental and control groups. Detection bias refers to “systematic differences in outcomes assessment among groups being compared.”9 Detection bias can occur because of inadequate assessor blinding and faulty measurement techniques. “Blinding of outcome assessors, especially with subjective outcome assessments,”9 and use of “valid and reliable measures”9 are intended to limit detection bias.

We assessed risk of bias separately for each outcome and each time point in each study. Each time point was assessed separately because longer followup often results in attrition or right-censoring, which may yield patients with characteristics that are different from the originally enrolled patients and also may introduce a systematic difference between the groups being compared. For this report, complete wound healing was the most important outcome to consider and the risk-of-bias assessment of this outcome is reported in Table 22 to Table 26.

We assessed risk-of-bias using the questions listed below. These questions address various areas of study design and conduct that influence the potential for bias in individual studies. The questions were modified to reflect important study design and conduct issues in wound care. Each of these questions was answered as “Yes,” “No,” or “Not Reported.” A “Yes” answer means that the study reported using this particular aspect of study design or conduct. A “No” answer means that the study reported that this particular aspect of study design or conduct was not used. A “Not Reported” answer means the publication did not provide sufficient information to determine whether the study did or did not use this particular aspect of study design or conduct. The questions are phrased so that a “Yes” answer reflects a lower risk-of-bias and a “No” reflects a higher risk-of-bias.

### Risk-of-Bias Questions

#### Selection Bias

1. Did the study use appropriate randomization methods?
2. Was there concealment of treatment-group allocation?
3. Were the mean wound sizes at the start of treatment similar (no more than a 15 percent difference) between groups?
4. Were the mean wound durations at the start of treatment similar (no more than a 15 percent difference) between groups?
5. Were the numbers of comorbidities similar (no more than a 15 percent difference) at the start of treatment between groups?

#### Detection Bias

6 Was the wound assessor blinded to the patient's treatment group?

#### Performance Bias

7 Outside of the skin substitute and comparator, did patients receive identical treatment for their wounds?

#### Attrition Bias

8 Did 85 percent or more of enrolled patients provide data at the time point of interest?
9 Was there a 15 percent or less difference in completion rates in the study arms?

We categorized the risk-of-bias for each outcome/time point in each study as “Low,” “Medium,” or “High” using the following method:

- Low potential for risk: No more than three “No” answers and Risk-of-Bias Question 7 (ancillary wound treatment) must be answered “Yes.”
- Moderate potential for risk: More than three “No” answers and Risk-of-Bias Question 7 (ancillary wound treatment) must be answered “Yes.”
- High potential for risk: Risk-of-Bias Question 7 (ancillary wound treatment) is answered “No.”
- Studies in which most of the questions can only be answered with “Not Reported” were considered to have an unclear risk-of-bias.

### Explanation of Risk-of-Bias Questions

#### Selection Bias

It is hoped that appropriate methods of randomization ensure that each study participant has the same chance of receiving each intervention.111,112 Appropriate randomization can be accomplished using computer software or a table of random numbers to assign patients to groups. Allocations by date of birth, date of admission, hospital numbers, or alternating patients are not appropriate randomization methods.

Concealment of group allocation prevents foreknowledge of group assignment in an RCT. This is distinct from patient or assessor blinding. The allocation process should be impervious to any influence by the individual making the allocation. Someone who is not responsible for recruiting participants, such as the hospital pharmacy or a central office should manage the randomization process and generate a random allocation sequence. Allocation using sequentially numbered, opaque, sealed envelopes avoids selection bias when a patient is assigned to treatment.

Differences in wound size, wound duration, or comorbidities between treatment arms have the potential to bias study results and mask true treatment effects. Proper random assignment of enrolled patients should ensure that these parameters are evenly distributed across study arms. Risk-of-Bias Questions 3, 4, and 5 are also tests of the randomization process.

#### Detection Bias

The FDA guidance document on chronic wound suggests that “blinding of subjects and investigators to the assigned treatment reduces bias and should be employed when feasible.”10 Other organizations interested in improving the quality of evidence in wound management have also suggested that blinding be a part of any study of chronic wounds. POWER considers blinding of “patients, clinical assessment, and analysts where possible” as part of a minimum set of criteria for RCTs.108 The European Wound Management Association (EWMA) believes that “outcome assessors should be blinded to interventions whenever possible.”106 The Center for Medical Technology Policy (CMTP) also recommends blinding the individual assessing wound healing outcomes.113 Blinding of patients to wound care treatment is not always possible because of visible differences in the treatment devices, dressings, or wound care routine. Therefore, we did not propose using a question related to blinding of patients as to their treatment. FDA has suggested that “in these situations, blinded assessment by a third-party evaluator should be considered.”10 Blinding of the individuals recording data on complete wound healing, wound size, and other outcomes should be possible and greatly minimizes the potential that results will be affected by the evaluator's expectations.106 Therefore, the wound assessor should be blinded to patient treatment (Risk-of-Bias Question 6). As mentioned earlier, FDA considers complete wound closure to be “one of the most objective” wound healing endpoints.10 Objective as opposed to subjective endpoints provide less opportunity for bias and “in general, blinding becomes less important to reduce observer bias as the outcomes become less subjective.”114

Computerized planimetry uses a digital image and computer software to outline the margins of a wound and determine the enclosed area.115 The main purpose of computerized planimetry is to accurately assess the surface area of a wound, not to determine if complete wound closure has occurred.115-118 FDA has suggested that photographic methods should be standardized for lighting, distance, exposure, and camera type.10 Little et al. have noted the need for accuracy, validity, reliability, consistency, and reproducibility in wound measurement techniques.119 As part of this report we have noted the methods used to assess wound size and condition at enrollment and during the course of a study. Because our primary outcome of interest was complete wound healing, we did not consider the use of computerized planimetry a substitute for assessor blinding.

#### Performance Bias

Performance bias is a “substantial challenge to avoid” when evaluating wound treatments and is prevented when all patients “receive exactly the same treatment with the exception of the study intervention.”106 The FDA guidance document also emphasizes that “good standard care procedures in a wound-treatment product trial are a prerequisite for assessing safety and efficacy of a product.”10 Wound care involves many steps including debridement to remove necrotic tissue from the wound, establishing a moist wound environment, controlling infection, and relieving pain. In any study of wound interventions with a low risk-of-bias, patients in both the experimental and control groups must receive comparable treatments outside of the experimental intervention (Risk-of-Bias Question 7). Such differences in treatment protocols between groups have the potential to introduce confounding factors that may mask the true treatment effect.

We consider identical treatment protocols an essential element in a low potential for risk study of wound treatments. Therefore, in our rating system for this report, we assigned a high risk-of-bias to a study if this criterion was not met or was not reported.

#### Attrition Bias

Assessment Questions 8 and 9 test whether patient attrition could potentially alter the patient characteristics sufficiently enough to bias study results.

#### Other Potential Biases

Funding of studies by a device manufacturer either directly or through support or employment of study authors has the potential to bias study results especially if important patient-oriented outcomes are not reported in a publication. However, all of the studies included in this review reported complete wound healing as their primary outcome. Therefore, we have not considered funding source as a potential source of bias in this assessment.

## Strength of the Evidence Base

Evidence-based Practice Centers judge the strength of an evidence base using the principles described by Owens et al.111 Risk-of-bias, consistency, directness, and precision are domains assessed by this process to judge the overall strength of an evidence base. Determining the risk-of-bias in the individual studies in an evidence base (as described above) is the first step in determining the overall strength of an evidence base. An evidence base consisting of studies with a high risk-of-bias implies a low strength of evidence. Consistency looks at “the degree to which reported effect sizes from included studies appear to have the same direction of effect.” Directness looks at “whether the evidence links the interventions directly to the health outcomes” and that the most important health outcomes are assessed. The use of intermediate or surrogate outcomes would be considered indirect evidence. Precision is “the degree of certainty surrounding an effect estimate” for each outcome and “a precise estimate should enable decision makers to draw conclusions about whether one treatment is, clinically speaking, inferior, equivalent (neither inferior not superior) or superior to another. For this report precision was judged by the statistical significance of risk differences for complete wound healing for a given comparison, as any improvement in rates of complete wound healing was considered clinically important. Individual studies with significant differences in rates of complete wound healing were considered precise. When meta-analysis was possible, the estimate was considered precise when the confidence interval was narrow enough to determine the direction of effect.

The overall strength of evidence for each outcome takes into account the assessments made for each of the domains described above and is graded as high, moderate, low, or insufficient. High signifies “high confidence that the evidence reflects the true effect” and no additional research is likely to change the “confidence in the estimate of effect.” Moderate signifies “moderate confidence that the evidence reflects the true effect” and future research may change the “confidence in the estimate of effect and may change the estimate.” Low signifies that we have limited confidence that the estimate of effect lies close to the true effect for this outcome, the body of evidence has major or numerous deficiencies (or both), and we believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect. Applicability is a separate consideration when judging the strength of an evidence base and is determined after the domains discussed above. Applicability is judged from the standpoint of clinical decision makers and how relevant the evidence is to them. The evidence must be evaluated to determine if the patient populations, settings, diseases or conditions, interventions, comparators, and outcomes are most relevant to their decisions. Thus, the evidence is assessed for its ability to reflect “real world” situations. The analytic framework serves to indicate the important patient populations, interventions, comparators, and outcomes important to applicability.

## Data Synthesis

This research synthesis is primarily qualitative in nature. We calculated absolute risk differences and relative risks (RR) with 95% confidence intervals for the outcome of complete wound healing at 12 weeks (where possible, or if not, the closest time point provided) for individual studies. We calculated odds ratios (OR) with 95% confidence intervals for individual studies where meta-analyses were possible, and calculated a summary OR using a random effects model. Studies were only combined using meta-analysis when populations and interventions were similar. Statistical heterogeneity was examined using I^2^, but the number of studies in the comparisons limited our confidence in measures of heterogeneity. No meta-regressions or subgroup analyses were anticipated or performed given the limited number of studies.