# Executive Summary

## Background

The Center for Medicare Management at the Centers for Medicare and Medicaid Services (CMS) requested this report from the Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the ECRI Institute Evidence-based Practice Center (EPC) (Contract Number: HHSA 290-2007-10063).

A wide variety of wound care products are available for clinicians to choose from when treating chronic wounds. Many of these products are said to mimic or substitute for some aspect of the skin's structure and function to promote healing and wound closure. The materials used to produce these products may be derived from human or animal tissue and may undergo extensive or minimal processing to make the finished product. The extent of processing and the source of the material used in the product also determines what regulatory pathway may be required before the product can be marketed. CMS requested this report on the types of wound care products that are commonly referred to as “skin substitutes” and on the regulatory pathways required for the different types of products. For this report, we have not created a definition for a skin substitute product. Instead we used the products listed under CMS codes Q4101 to Q4122 as a starting point and looked for similar products listed in the U.S. Food and Drug Administration (FDA) product codes to generate a list of products. We included only those products indicated for chronic wounds. We note that FDA does not refer to any product or class of products as “skin substitutes,” and we are not proposing an official classification system.

In addition to identification of the products, a second objective of this review was to begin to characterize the state of the evidence base on skin substitutes as wound care products. To address this objective, we sought to determine the number of RCTs of these products and to assess the efficacy of skin substitutes under the conditions presented in the trials. Systematically reviewing and analyzing all the clinical research on skin substitutes is beyond the scope of this report.

This report specifically examined the use of skin substitutes for treating the following chronic wound types: diabetic foot ulcers, pressure ulcers, and vascular ulcers (including venous ulcers and arterial ulcers). Treatment of burn wounds with skin substitutes is outside the scope of this report.

The skin's functions are performed by three distinct tissue layers: a thin outer layer of cells called the epidermis, a thicker middle layer of connective tissue called the dermis, and an inner, subcutaneous layer. The outer layers of the epidermis are composed of flattened, cornified dead keratinocytes that form a barrier to water loss and microbe entry. These cells are derived from a basal layer of constantly dividing keratinocytes that lies next to the dermis. The dermis is composed mostly of collagen fibers and some elastic fibers produced by fibroblasts that, along with water and large proteoglycan molecules, make up the extracellular matrix. This layer of the skin provides mechanical strength and a substrate for water and nutrient diffusion; it contains blood vessels, nerves, and cells involved in immune function, growth, and repair. The dermis also contains sweat glands, oil glands, and hair follicles. The subcutaneous layer is composed of adipocytes that form a thick layer of adipose tissue.1

Wounds are breaches in the structure of the skin that compromise skin function. Chronic wounds have not completed the healing process (restoring tissue loss and skin function) in the expected time frame, usually within 30 days;2 have not responded to initial treatment; or persist despite appropriate care.3 These wounds usually do not close without interventions. Diabetic foot ulcers, venous leg ulcers, and pressure ulcers are the chronic wounds most often treated with skin substitute products.

Skin substitutes were developed as an alternative to skin grafts for burn patients. Autologous tissue grafting is an invasive and painful procedure, and the extent of damaged skin is often too large to be covered by autologous tissue graft alone. However, skin substitutes are now primarily used in treating chronic wounds rather than for burns, in part because chronic wounds are far more common than burn wounds.4

A true “skin substitute” would act like an autologous skin graft in adhering to the wound bed while providing the physiological and mechanical functions of normal skin.4 The skin substitutes included in this report contain various combinations of cellular and acellular components intended to stimulate the host to regenerate lost tissue and replace the wound with functional skin. Presumably, successful healing during management with these products would also require maintenance of a moist wound environment and other procedures thought to promote healing. These include removal of exudate and necrotic tissue, infection control, nutritional support, pressure avoidance (e.g., off-loading for diabetic foot ulcers and pressure ulcers), and edema control (e.g., compression for venous leg ulcers).5

Dieckmann et al. have suggested that skin substitutes can be divided into two broad categories: biomaterial and cellular.5 Biomaterial skin substitutes do not contain cells (acellular) and are derived from natural or synthetic sources. Natural sources include human cadaver skin processed to remove the cellular components and retain the structural proteins of the dermis and collagen matrix obtained from bovine and porcine sources. Synthetic sources include various degradable polymers such as polylactide and polyglycolide. Whether natural or synthetic, the biomaterial provides an extracellular matrix that allows for infiltration of surrounding cells. Cellular skin substitutes are distinguished by their origin: xenogeneic (from nonhuman species), autologous (from the patient), and allogenic (from another human). Keratinocytes and fibroblasts obtained from these sources are cultured in vitro to produce the cellular material used to make the substitute. However, the division of skin substitutes into either biomaterial or cellular is not completely accurate because the two are combined in several wound care products (see Table 2).

Table 2 Human- and human/animal-derived products regulated through the premarket approval (PMA) or humanitarian device exemption (HDE) process

Product and Manufacturer | Product Description | Approval Date | FDA Product Code | FDA Intended Use/Indication for Use
Apligraf/Graftskin -Organogenesis | Apligraf is supplied as a bilayered skin substitute: the epidermal layer is formed by human keratinocytes and has a well differentiated stratum corneum, the dermal layer is composed of human fibroblasts in a bovine type I collagen lattice. Human fibroblasts and keratinocytes were derived from neonatal foreskins. | 1998 PMA original 2000 PMA added diabetic ulcers | MGR (dressing, wound and burn, interactive) | “For use with standard therapeutic compression for the treatment of non-infected partial and full-thickness skin ulcers due to venous insufficiency of greater than 1 month duration and which have not adequately responded to conventional ulcer therapy. Apligraf is also indicated for use with standard diabetic foot ulcer care for the treatment of full-thickness neuropathic diabetic foot ulcers of greater than three weeks duration which have not adequately responded to conventional ulcer therapy and which extend through the dermis but without tendon, muscle, capsule or bone exposure.”
Dermagraft - Advanced Biohealing, Inc. and Smith & Nephew | Cryopreserved human fibroblast-derived dermal substitute on a bioabsorbable polyglactin mesh scaffold. The fibroblasts are obtained from human newborn foreskin tissue. | 2001 PMA | MGR (dressing, wound and burn, interactive) | “For use in the treatment of full-thickness diabetic foot ulcers greater than six weeks' duration which extend through the dermis, but without tendon muscle, joint capsule or bone exposure. Dermagraft(r) should be used in conjunction with standard wound care regimens and in patients that have adequate blood supply to the involved foot. Dermagraft is contraindicated for use in ulcers that have signs of clinical infection or in ulcers with sinus tracts. Dermagraft is contraindicated in patients with known hypersensitivity to bovine products, as it may contain trace amounts of bovine proteins from the manufacturing medium and storage solution.”

MGR is one of the FDA product codes designated for Class III devices

FDA regulates products commonly referred to as “skin substitutes” under one of four categories, depending on the product's origin and composition: human-derived products regulated as human cells, tissues, and cellular and tissue-based products (HCT/Ps); human- and human/animal-derived products regulated through premarket approval (PMA) or as a Humanitarian Use Device (HUD) obtained through a humanitarian device exemption (HDE); or as animal-derived products and synthetic products regulated under the 510(k) process.6-8

Human tissue can be obtained from human donors, processed, and used exactly in the same role in the recipient (e.g., skin for skin, tendon for tendon, bone for bone). These uses are regulated as human tissue intended for transplantation (HCT/Ps) as long as the proposed clinical use and manufacturing methods are consistent with definitions of “Homologous Use” and “Minimal Manipulation” cited in 21 CFR (Code of Federal Regulations) 1271. Human tissue and cells may also be used as a source of cells for culturing to produce cellular-derived material for wound healing. These products may be regulated under the Biologics License Application (BLA) (under the Federal Public Health Service [PHS] Act) or PMA/HDE (under the Federal Food, Drug and Cosmetic [FD&C] Act), depending on their composition and primary mode of action.

Many medical products intended for use in treating wounds are derived from animals. Porcine and ovine tissues and skin are processed into sheets for use as skin substitutes. Bovine fetal tissue is a source of skin cells that are grown in culture to produce skin substitutes. These products may be regulated under the 510(k) process if an appropriate predicate device exists with an equivalent composition and intended use and if the proposed product does not raise any different types of safety or effectiveness questions. When a product does not meet these criteria, it may be reviewed in BLA (PHS Act) or PMA/HDE (FD&C Act) applications, depending on the composition and primary mode of action.

Wound care products regulated under the PMA process are indicated for treating a subset of chronic wounds, those wounds with more than 30 days' duration that have not adequately responded to standard wound care. The 510(k) products are indicated for managing chronic wounds and no restrictions are put on wound duration or prior treatments.

Establishments producing products regulated as HCT/Ps are required to register with FDA and list their HCT/Ps products, but they are not required to demonstrate the safety or effectiveness of their HCT/Ps products. Establishments producing devices regulated under the PMA process must submit an application containing the results of scientifically valid clinical investigations demonstrating that the device is effective and safe for its intended purpose before it can be approved for marketing.

To obtain approval for an HUD, an HDE application is submitted to FDA. An HDE is similar in both form and content to a PMA application but is exempt from the effectiveness requirements of a PMA. HDE approval is based on evidence of probable benefit in a disease population occurring at a frequency of fewer than 4,000 patients per year in the United States. An HDE application is not required to contain the results of scientifically valid clinical investigations demonstrating that the device is effective for its intended purpose. The application, however, must contain sufficient information for FDA to determine that the device does not pose an unreasonable or significant risk of illness or injury and that the probable benefit to health outweighs the risk of injury or illness from its use, taking into account the probable risks and benefits of currently available devices or alternative forms of treatment. Additionally, the applicant must demonstrate that no comparable devices are available to treat or diagnose the disease or condition and that they could not otherwise bring the device to market.

## Methods of the Review

The process of systematic review as practiced by AHRQ's EPC Program follows specific prescribed steps:

1. The investigators start with formulated key questions. These questions test hypotheses and are structured using the PICO framework: patients, intervention of interest, comparator, and outcomes. EPCs are encouraged to focus on outcomes that are relevant and important to patients (patient-centered outcomes). The framework is depicted visually in the analytic framework that the EPC Program uses to show the relationship between the key questions and the outcomes used to address these questions (see Figure 1).
2. Inclusion and exclusion criteria for studies to be used in the review are determined based on the specific questions to be addressed. Criteria may vary for each question in the review.
3. Next, an objective and comprehensive search of the medical literature and gray literature (i.e., reports, monographs, and studies produced by government agencies, educational facilities, and corporations that do not appear in the peer-reviewed literature) is conducted. The reference lists of included studies are examined for any studies not identified by electronic searches.
4. Studies are compared with the inclusion criteria developed before examining the evidence, and those included in the review are then critically appraised, noting features of the design and conduct of the studies that create a potential for bias. Risk of bias, in this context, is the extent to which the design and conduct of a single study “protect against all bias in the estimate of treatment effect.”9 Studies with a low risk for bias are typically described as being of “high” quality, whereas those with high risk for bias are described as being of “low” or “poor” quality, and those of “moderate quality” as having intermediate risk for bias. The degree to which a study protects against bias is referred to as “internal validity.” Following this appraisal, data are extracted from the included studies and analyzed or summarized as appropriate.

Figure 1 Analytic framework

Figure 1 is an analytic framework that depicts the events that patients undergoing treatment for chronic wounds may experience. The framework includes from left to right the patient population of interest, treatment comparisons, patient-oriented outcomes and adverse effects that may occur from treatment. In the first frame, we have our patient population of interest, “patients with a chronic wound.” For this report, only adults with chronic wounds will be included. An arrow leads the patient to treatments by either skin substitutes or other wound treatments. Next, the path leads to a third frame, the patient-oriented outcomes. First, we list percentage of completely closed/healed wounds. Listed below in separate boxes are additional patient-oriented outcomes of interest: time to complete wound closure, wound reoccurrence, wound infection, need for amputation, need for hospitalization, return to baseline activities of daily living and function, pain reduction, exudate and odor reduction. Lastly, an arrow connects all treatments to the topic of adverse effects which may occur due to treatment.

Upon receipt of the work assignment for this review in August 2011, we developed the following Key Questions:

1. What are the U.S. Food and Drug Administration (FDA)-regulated skin substitutes that fall under each of the following pathways: PMA, 510(k), PHS 361 [21 CFR 1270 & 1271]?
  a. PMA: Premarket approval by FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices. Class III devices support or sustain human life, are of substantial importance in preventing impairment of human health, or present a potential, unreasonable risk of illness or injury.
  b. 510(k): A 510(k) is a premarketing submission made to FDA to demonstrate that the device to be marketed is as safe and effective, that is, substantially equivalent, to a legally marketed device that is not subject to PMA.
  c. PHS 361 [21 CFR 1270 & 1271]: HCT/Ps (Human cells, tissues, and cellular and tissue-based products). Creates a unified registration and listing system for establishments that manufacture HCT/Ps and establishes donor eligibility, current good tissue practice, and other procedures to prevent the introduction, transmission, and spread of communicable diseases by HCT/Ps.
2. For patients with chronic wounds (pressure ulcers, diabetic foot ulcers, venous leg ulcers, or arterial leg ulcers), are skin substitutes more effective than other wound care options (usual or standard care, or usual or standard care plus synthetic dressings, growth factors, skin grafts, or other treatments used as a comparison) in promoting wound healing for the following outcome measures:
  a. Percentage of completely closed/healed wounds (skin closure with complete re- epithelialization without drainage or dressing requirements)
  b. Time to complete wound closure
  c. Wound reoccurrence
  d. Wound infection
  e. Need for amputation
  f. Need for hospitalization (frequency and duration)
  g. Return to baseline activities of daily living and function
  h. Pain reduction
  i. Exudate and odor reduction
3. What type and frequency of adverse events are reported in the clinical literature for each of the FDA-regulated skin substitute products?

In addressing the key questions, we sought the specific outcomes depicted in the analytic framework in Figure 1. Key Questions 2 and 3 are represented in the framework by a circled number. Key Question 1 is not related to treatment and outcomes and is not depicted in the figure. According to a guidance document prepared by FDA in 2006, clinical outcomes associated with the use of a wound-treatment product or device can be broadly grouped into two categories: improved wound healing and improved wound care.10 Several outcomes or endpoints fall into these two categories. According to the FDA document, “complete wound closure of a chronic nonhealing wound is one of the most objective and clinically meaningful wound healing endpoints” and “complete wound closure is defined as skin reepithelialization without drainage or dressing requirements at two consecutive study visits 2 weeks apart.”10 We therefore selected complete wound healing as the primary patient-centered outcome for this report.

Inclusion criteria were then developed to specify the types of studies appropriate for addressing each of the key questions. These criteria are explained in detail in the “Methods” section of this report but are briefly described here. To address Key Question 1 we started with the list of skin substitute products listed in CMS codes Q4101 to Q4122 and looked to see which FDA product codes the these products were included under. We added similar products with the same FDA product code. The list of products was then screened to exclude products that were not indicated for chronic wounds. To address Key Questions 2 and 3, we included only randomized controlled trials that enrolled human subjects who had received a diagnosis of a chronic wound (pressure ulcer, diabetic foot ulcer, venous leg ulcer, or arterial leg ulcer) lasting more than 30 days without healing and examined the efficacy of a commercially available skin substitute product regulated by FDA.

Searches were undertaken of 13 electronic bibliographic databases from 1966 to the present for published primary clinical studies and any secondary publications. To supplement the electronic searches, we manually reviewed the reference lists of studies meeting inclusion criteria. Abstracts were reviewed, potential references retrieved, and then full articles were reviewed. Figure 2 is an attrition diagram that provides a visualization of the disposition of materials as they were evaluated for possible inclusion in the report.

Figure 2 Disposition of documents identified by searches

Figure 2 is an attrition diagram that depicts the status of documents identified by internal literature searches. The diagram begins with a box outlining the 95 citations identified. Several boxes ensue which are connected by arrows going from top to bottom which follow the citations as they are being screened for possible inclusion in the report. In the first frame we remove articles at the abstract level that are not relevant to the report. 60 citations were excluded. The path then follows the 35 full articles retrieved. During this phase of screening we do a more extensive screening of the articles based on our pre-determined inclusion/exclusion criteria. See our Methods Section for additional information on the criteria. 20 articles were excluded during this evaluation phase. Three studies were added after comments were reviewed leaving 18 articles that met our inclusion criteria.

Additionally, we searched for ongoing clinical trials using ClinicalTrials.gov and Controlled-trials.com.

See Table 20 and Table 21 for explanations for exclusions at the abstract and full-article levels.

The most common reasons for exclusion of retrieved articles were the following:

- Study was not a randomized controlled trial.
- Product is not commercially available in the United States.
- Study was a narrative review.
- Publication duplicated an already included study.

Next, an assessment of the potential for bias of the included studies was performed following procedures adopted by EPCs and using a risk-of-bias assessment instrument developed by ECRI Institute specifically for comparative studies of wound care interventions. The overall strength of the evidence base was also judged by following procedures adopted by EPCs and includes assessment of consistency of effect, directness of effect, and precision of the effect estimate.

## Evidence for Skin Substitutes

### Key Question 1 What are the U.S. Food and Drug Administration (FDA)-regulated skin substitutes that fall under each of the following pathways: PMA, 510(k), PHS 361 [21 CFR 1270 & 1271]?

Definitions
a. PMA: Premarket approval by FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices. Class III devices support or sustain human life, are of substantial importance in preventing impairment of human health, or present a potential, unreasonable risk of illness or injury.
b. 510(k): A 510(k) is a premarketing submission made to FDA to demonstrate that the device to be marketed is as safe and effective, that is, substantially equivalent, to a legally marketed device that is not subject to PMA.
c. PHS 361 [21 CFR 1270 & 1271]: HCT/Ps. Creates a unified registration and listing system for establishments that manufacture human cells, tissues, and cellular and tissue- based products (HCT/Ps and establishes donor eligibility, current good tissue practice, and other procedures to prevent the introduction, transmission, and spread of communicable diseases by HCT/Ps.

This section of the report addresses which skin substitute products are currently regulated by FDA for use in the United States for treating or managing chronic wounds. This question does not address clinical effectiveness or efficacy. Our searches identified several products that are intended as skin substitutes but may also be used for other medical purposes. Our search results, contained in the following tables, are likely not comprehensive, and other products may fit this report's collection of a skin substitutes that were not identified by our searches. Based on the FDA regulations that govern each product we identified and the origin and composition of the products, skin substitutes can be organized into four groups: human-derived products regulated as HCT/Ps (see Table 1), human- and human/animal-derived products regulated through PMA or humanitarian device exemption (HDE) (see Table 2), animal-derived products regulated under the 510(k) process (see Table 3), and synthetic products regulated under the 510(k) process (see Table 4). Our searches identified 57 skin substitute products.

Table 1 Human-derived products regulated solely under 21 CFR 1271 (HCT/Ps)

Product | Manufacturer | Description
AlloDerm Regenerative Tissue Matrix | LifeCell, KCI | Acellular human dermis product
Allopatch HD | Musculoskeletal Transplant Foundation | Acellular human dermis product
Alloskin | AlloSource | Allograft derived from epidermal and dermal cadaveric tissue
Cymetra Micronized AlloDerm | LifeCell, KCI | Injectable form of AlloDerm Regenerative Tissue Matrix
Dermacell | LifeNet Health | Acellular human dermis product
Flex HD | Ethicon and Musculoskeletal Transplant Foundation | Acellular hydrated dermis derived from donated human allograft skin
GammaGraft | Promethean LifeSciences, Inc. | Irradiated cadaveric human skin allograft
Graftjacket | Life Cell, licensed to Wright Medical Technology and KCI | Processed human dermal matrix
Matrix HD | RTI Biologics | Acellular human dermis product
Memoderm | Memometal Inc. | Acellular human dermis product
Puros Dermis | Zimmer Dental | A natural biological matrix
Repliform | LifeCell and Boston Scientific | Acellular human dermis product
TheraSkin | Soluble Systems | Biologically active cryopreserved human skin allograft with both epidermis and dermis layers

HCT/Ps: Human cells, tissues, and cellular and tissue-based products

Table 3 Animal-derived products regulated under the 510(k) process

Product and Manufacturer | Description | Clearance Date | FDA Product Code | FDA Intended Use/Indication for Use
ACell UBM Hydrated Wound Dressing – ACell, Incorporated11 | A wound dressing primarily composed of porcine collagen. | 2002 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
ACell UBM Lyophilized Wound Dressing – ACell, Incorporated12 | A wound dressing primarily composed of porcine collagen. | 2002 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds. The device is intended for one-time use.”
Aongen™ Collagen Matrix – Aeon Astron Europe B.V.13 | A biodegradable material composed of collagen. | 2009 | KGN (dressing, wound, collagen) | “For the management of wounds including: surgical wounds, trauma wounds, draining wounds, second degree burns, partial and full-thickness wounds, pressure ulcers, venous ulcers, vascular ulcers, diabetic ulcers, and oral wounds and sores.”
Atlas Wound Matrix – Wright Medical Technology, Inc.14 | A sterile, decellularized fenestrated or nonfenestrated processed porcine collagen dermal material. | 2009 | KGN (dressing, wound, collagen) | For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), draining wounds. The Atlas Wound Matrix is a collagen wound dressing that provides an environment that supports wound healing.”
Avagen Wound Dressing – Integra LifeSciences Corp.15 | A wound dressing comprised of a porous matrix of cross-linked bovine tendon collagen and glycosaminoglycan. The biodegradable matrix provides a scaffold for cellular invasion and capillary growth. | 2002 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds.”
Collagen Sponge – Innocoll Pharmaceuticals16 | A collagen matrix sponge | 2010 | KGN (dressing, wound, collagen) | “For the management of wounds such as: pressure ulcers, venous stasis ulcers, diabetic ulcers, first and second degree burns, partial and full thickness wounds, and superficial injuries.”
Collagen Wound Dressing – Oasis Research, LLC17 | A wound care dressing composed of hydrolyzed bovine collagen. | 2000 | KGN (dressing, wound, collagen) | “For the management of wounds including full thickness and partial thickness wounds, pressure ulcers, venous ulcers, ulcers caused by mixed vascular etiologies, diabetic ulcers, second-degree burns, donor sites and other bleeding surface wounds, abrasions, traumatic wounds healing by secondary intention, dehisced surgical incisions.”
Collaguard™ – Innocoll Pharmaceuticals18 | A clear collagen matrix film | 2006 | KGN (dressing, wound, collagen) | “For the management of wounds such as: pressure ulcers, venous stasis ulcers, diabetic ulcers, first and second degree burns, partial and full thickness wounds, and superficial injuries.”
CollaSorb™ Collagen Wound Dressing – Hartmann-Conco Inc.19 | A wound care product composed of native collagen and calcium-alginate. | 2009 | KGN (dressing, wound, collagen) | “For the management of full and partial thickness wounds including: pressure ulcers, diabetic ulcers, ulcers caused by mixed vascular etiologies, venous ulcers, second degree burns, donor and graft sites, abrasions, dehisced surgical wounds, and traumatic wounds healing by secondary intention.”
CollaWound™ dressing – Collamatrix Inc.20 | A sterile, single use, disposable wound dressing device comprised of insoluble fibrous collagen derived from porcine. | 2006 | KGN (dressing, wound, collagen) | “For the management of partial and full thickness wounds, pressure ulcers, venous ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds, first and second degree burns, surgical wounds and superficial injuries.”
Collexa^®^ – Innocoll Pharmaceuticals21 | A collagen matrix sponge | 2010 | KGN (dressing, wound, collagen) | “For the management of wounds such as: diabetic ulcers, venous ulcers, pressure ulcers, ulcers caused by mixed vascular etiologies, full-thickness and partial-thickness wounds, abrasions, traumatic wounds, first and second degree burns, dehisced surgical wounds, and exuding wounds.”
Collieva^®^ – Innocoll Pharmaceuticals22 | A clear collagen matrix film | 2008 | KGN (dressing, wound, collagen) | “For the management of wounds such as: pressure ulcers, venous stasis ulcers, diabetic ulcers, first and second degree burns, partial and full thickness wounds, and superficial injuries.”
Coreleader Colla-Pad – Coreleader Biotech Co., Ltd.23 | A porous matrix consisting of cross-linked bovine collagen. | 2011 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, skin tears) and draining wounds.”
Dermadapt™ Wound Dressing – Pegasus Biologics, Inc.24 | A collagen-based wound dressing described as a decellularized, equine pericardial implant. | 2006 | KGN (dressing, wound, collagen) | “For the management of moderately to heavy exuding wounds, including: partial and full thickness wounds, draining wounds, pressure sores/ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds (e.g., abrasions, lacerations, partial thickness burns, skin tears), and surgical wounds (e.g., donor sites/grafts, post-laser surgery, post-Mohs surgery, podiatric wounds, dehisced surgical incisions).”
DressSkin – TEI Biosciences Inc.25 | A wound dressing composed of hydrolyzed bovine collagen. | 2003 | KGN (dressing, wound, collagen) | “For the management of wounds that include: partial and full thickness wounds; pressure, diabetic, and venous ulcers; second-degree burns; surgical wounds—donor sites/grafts, post Mohs surgery, post-laser surgery, podiatric, wound dehiscence; trauma wounds—abrasions, lacerations, and skin tears; tunneled/undermined wounds; draining wounds.”
E-Z Derm - AM Scientifics, Ltd26 | Biosynthetic wound dressing made from porcine tissue. | 1994 | KGN (dressing, wound, collagen) | No FDA summary available online
EndoForm Dermal Template™ – Mesynthes27 | Extracellular matrix derived from ovine forestomach. | 2010 | KGN (dressing, wound, collagen) | “For single use in the [underlined: treatment] of the following wounds: partial and full-thickness wounds; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled/undermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, second-degree burns, and skin tears); draining wounds.”
Excellagen – Tissue Repair Company28 | A wound care device composed of formulated, 2.6% (26 mg/mL) fibrillar bovine dermal collagen (Type I). | 2011 | KGN (dressing, wound, collagen) | “For the management of wounds including partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds.”
FortaDerm™ Wound Dressing – Organogenesis, Inc.29 | A single-layer fenestrated sheet of porcine intestinal collagen. | 2001 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post laser surgery, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds.”
HA Absorbent Wound Dressing – ConvaTec, A Division of E.R. Squibb and Sons, Inc.30 | An absorbent fibrous fleece (F) or rope (R), entirely composed of HYAFF 11p75™, a benzyl ester of hyaluronic acid. | 1999 | KGN (dressing, wound, collagen) | “For over-the-counter use, HA Absorbent Wound Dressing-F may be used for wounds such as: abrasions, lacerations, minor cuts and first degree burns. Under the supervision of a healthcare professional, HA Absorbent Wound Dressing-F may be used for wounds such as: leg ulcers, pressure ulcers (stages I-IV), and diabetic ulcers, surgical wounds (post-operative, donor sites, dermatological), second degree burns; management of wounds that are prone to bleeding such as wounds that have been mechanically or surgically débrided, donor sites, and traumatic wounds. HA Absorbent Wound Dressing-R is indicated for use in the management of deep exuding wounds, sinuses, and fistulae.”
Helicoll – ENCOLL Corp.31 | A translucent, off-white, semi-occlusive, self-adhering and ready to use pre-sterilized Type-1 Collagen Sheet. | 2004 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds (abrasions, lacerations, second-degree burns, skin tears), and surgical wounds (donor sites/grafts, post-Mohs' surgery, post-laser surgery, podiatric), wound dehiscence.”
Integra™/Bilayer Matrix Wound Dressing - Integra Lifesciences Corp.32 | Bilayered matrix composed of a porous layer of cross-linked bovine tendon collagen and glycosaminoglycan and a semipermeable polysiloxane (silicone) layer. | 2002 | FRO (dressing, wound, drug) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic and vascular ulcers, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears) and draining wounds.”
Integra™ Flowable Wound Matrix33 | A wound care device comprised of granulated cross-linked bovine tendon collagen and glycosaminoglycan. | 2007 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, skin tears) and draining wounds.”
LTM Wound Dressing – LifeCell Corp.34 | A terminally sterilized sheet of the processed porcine dermal matrix | 2008 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post laser surgery, podiatric wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns and skin tears), draining wounds, and other bleeding surface wounds.”
MatriStem - ACell, Inc.35 | Extracellular matrix product derived from porcine urinary bladder tissue. | 2009 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, skin tears) and draining wounds.”
MatriStem^®^ Wound Matrix – ACell, Inc.36 | A sterile, porcine-derived, naturally-occurring lyophilized extracellular matrix sheet. | 2011 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunnel/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
Matrix Collagen Wound Dressing – Collagen Matrix, Inc.37 | An opaque, absorbent, collagen membrane matrix intended for topical use. | 2004 | KGN (dressing, wound, collagen) | “For the management of moderately to heavily exudating wounds and to control minor bleeding. Collagen Topical Wound Dressing may be used for the management of exudating wounds such as: pressure ulcers, venous stasis ulcers, diabetic ulcers, acute wounds (for example trauma and surgical wounds), and partial thickness burns.”
Medline Collagen Wound Dressing – Medline Industries, Inc.38 | Not available in 510(k) clearance information. | 2006 | KGN (dressing, wound, collagen) | “For the management of wounds including: full thickness and partial thickness wounds, pressure ulcers, venous ulcers, ulcers caused by mixed vascular etiologies, diabetic ulcers, partial and full thickness burns, donor sites and other bleeding surface wounds, abrasions, traumatic wounds healing by secondary intention, and dehisced surgical incisions. These dressings may be cut to size and may be layered for the management of deep wounds.”
Oasis^®^ - Cook Biotech, Inc.39 | Extracellular matrix derived from porcine small intestinal submucosa | 2006 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled, undermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, second-degree burns, and skin tears); draining wounds.”
Primatrix™ – TEI Biosciences Inc.40 | Acellular dermal tissue matrix. | 2008 | KGN (dressing, wound, collagen) | “For the management of wounds that include: partial and full thickness wounds; pressure, diabetic, and venous ulcers; second-degree burns; surgical wounds-donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence; trauma wounds-abrasions, lacerations, and skin tears; tunneled/undermined wounds; and draining wounds.”
Primatrix™ Dermal Repair Scaffold - TEI Biosciences41 | Extracellular matrix dermal substitute derived from fetal bovine dermis collagen. | 2006 | KGN (dressing, wound, collagen) | “For the management of wounds that include: partial and full thickness wounds; pressure, diabetic, and venous ulcers; second degree burns; surgical wounds-donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence; trauma wounds-abrasions, lacerations, and skin tears; tunneled/undermined wounds; draining wounds.”
SIS Wound Dressing II – Cook Biotech, Incorporated42 | A wound dressing primarily composed of porcine collagen. | 2000 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
SS Matrix™ – Cook Biotech Incorporated43 | A matrix product primarily composed of porcine collagen. | 2002 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
Stimulen™ Collagen – Southwest Technologies, Inc.44 | A sterile primary single use dressing comprised of soluble modified bovine collagen base. | 2004 | KGN (dressing, wou nd, collagen) | “For the management of wounds including full and partial thickness wounds, pressure ulcers (stages I-IV), venous stasis ulcers, diabetic ulcers, partial thickness burns, acute wounds, abrasions, traumatic wounds healing by secondary intention, donor sites and other surface wounds.”
TheraForm™ Standard/Sheet – Sewon Cellontech Co., Ltd.45 | An absorbable collagen membrane derived from porcine. | 2009 | KGN (dressing, wound, collagen) | “For the management of wounds including: partial and full-thickness wounds, pressure ulcers, venous ulcers, diabetic ulcers, chronic ulcers, tunneled/undermined wounds, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, second-degree burns, and skin tears), and draining wounds.”
Unite^®^ Biomatrix – Synovis Orthopedic and Woundcare, Inc.46 | A decellularized equine pericardial extracellular matrix (xenograft) | 2011 | KGN (dressing, wound, collagen) | “For the management of moderately to severely exudating wounds, including: partial and full thickness wounds, draining wounds, pressure sores/ulcers, venous ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds (e.g., abrasions, lacerations, partial thickness [second-degree] burns, skin tears), surgical wounds (e.g., donor sites/grafts, post-laser surgery, post-Mohs surgery, podiatric wounds, dehisced surgical incisions).”
Unite™ Biomatrix – Pegasus Biologics, Inc.47 | A collagen-based wound dressing consisting of decellularized, equine pericardium. | 2007 | KGN (dressing, wound, collagen) | “For the local management of moderately to heavy exuding wounds including: partial and full thickness wounds, draining wounds, pressures sores/ulcers, venous ulcers, chronic vascular ulcers, diabetic ulcers, trauma wounds (e.g., abrasions, lacerations, partial thickness burns, skin tears), surgical wounds (e.g., donor sites/grafts, post-laser surgery, post-Mohs surgery, podiatric wounds, dehisced surgical incisions).”

KGN and FRO are among the FDA product codes designated for unclassified pre-amendment devices.

Table 4 Biosynthetic products regulated under the 510(k) process

Product and Manufacturer | Description | Clearance Date | FDA Product Code | FDA Intended Use/Indication for Use
Hyalomatrix KC Wound Dressing (Laserskin) - Anika Therapeutics48 | Hyalomatrix is a bilayered wound dressing composed of a nonwoven pad made of a benzyl esters of hyaluronic acid (HYAFF) and a semipermeable silicone membrane. | 2001 | MGP (dressing, wound and burn, occlusive) | “For the management of wounds in the granulation phase such as pressure ulcers, venous and arterial leg ulcers, diabetic ulcers, surgical incisions, second degree burns, skin abrasions, lacerations, partial-thickness grafts and skin tears, wounds and burns treated with meshed grafts. It is intended for use as a temporary coverage for wounds and burns to aid in the natural healing process.”
Hyalomatrix Wound Dressing - Anika Therapeutics S.r.l.49 | Hyalomatrix is a bilayered wound dressing composed of a nonwoven pad made of HYAFF 11 (a benzyl ester of hyaluronic acid) and a semipermeable silicone membrane. | 2007 | FRO (dressing, wound, drug) | “For the management of wounds including: partial and full-thickness wounds; second-degree burns; pressure ulcers; venous ulcers; diabetic ulcers; chronic vascular ulcers; tunneled/undetermined wounds; surgical wounds (donor sites/grafts, post-Mohs surgery , post-laser surgery, podiatric, wound dehiscence); trauma wounds (abrasions, lacerations, skin tears); and draining wounds.”
Jaloskin - Anika Therapeutics S.r.l.50 | Jaloskin is a semipermeable, transparent film dressing, composed of HYAFF 11 (a benzyl ester of hyaluronic acid) only | 2010 | FRO (dressing, wound, drug) | “For the management of superficial moderately exuding wounds including pressure ulcers, venous ulcers, diabetic ulcers, chronic vascular ulcers, surgical wounds (donor sites/grafts, post-Mohs surgery, post-laser surgery, podiatric, wound dehiscence), trauma wounds (abrasions, lacerations, skin tears) and first and second degree bums.”
Suprathel - Polymedics Innovations51 | Synthetic, biocompatible, and absorbable skin substitute made from polymers of lactic acid. | 2009 | FRO (dressing, wound, drug) | “For temporary coverage of non-infected skin defects, such as superficial wounds, under sterile conditions. The dressing is intended to maintain a moist wound healing environment. A moist wound healing environment allows autolytic debridement. The Suprathel Wound and Burn Dressing is used in the management of: Partial and full thickness wounds; Pressure (stage I and IV) and venous ulcers; Ulcers caused by mixed vascular etiologies; Venous stasis and diabetic ulcers; 1st and 2nd degree bums; Partial thickness bums; Cuts and abrasions; Acute wounds; Trauma wounds; Surgical wounds; Superficial wounds; Grafted wounds and donor sites.”
Talymed™ – Marine Polymer Technologies, Inc.52 | A sterile wound matrix comprised of shortened fibers of poly-N-acetylglucosamine, isolated from microalgae. | 2010 | FRO (dressing, wound, drug) | “For the management of wounds including: diabetic ulcers; venous ulcers; pressure wounds; ulcers caused by mixed vascular etiologies; full thickness and partial thickness wounds; second degree burns; surgical wounds-donor sites/grafts, post-Mohs surgery, post laser surgery, and other bleeding surface wounds; abrasions, lacerations; traumatic wounds healing by secondary intention; chronic vascular ulcers; dehisced surgical wounds.”

KGN, MGP, and FRO are among the FDA product codes designated for unclassified pre-amendment devices.

HYAFF: Benzyl esters of hyaluronic acid

Table 2 indicates that skin substitute products using human fibroblasts and keratinocytes (derived from neonatal foreskins) and combined with other acellular components are regulated under the PMA process and receive the FDA product code MGR (dressing, wound and burn, interactive). For these products, the term “treatment” is used in the indications for use with chronic wounds. Each of the PMA entries in Table 2 is actually a combination of living human cells and another component (bovine collagen in Apligraf^®^ and polyglactin mesh in Dermagraft^®^). FDA considers these to be combination products (i.e., combinations of device and biological components into a single entity) and regulates them as medical devices. Besides providing a biologic wound covering, these products also contain human cells capable of producing human growth factors and cytokines that may stimulate angiogenesis, tissue expansion, and re-epithelialization.5 Thus, these products may interact with the wound bed and assist in the wound healing process. The indications for use of these products are also more specific compared with products regulated under the 510(k) process. The wounds must be noninfected, greater than one month in duration, and unresponsive to conventional treatment.

Table 3 and Table 4 indicate that skin substitute products considered Class II devices and regulated under the 510(k) process are included in FDA product codes KGN (dressing, wound, collagen), FRO (dressing, wound, drug), and MGP (dressing, wound and burn, occlusive) and use the term “management” of wounds in the indications for use on chronic wounds. These products use animal tissue collagen or synthetic material to create an extracellular matrix that acts as a wound covering and scaffold for tissue invasion and regrowth. They do not contain human cells and, therefore, do not have a natural source of growth factors or cytokines involved in initiating the wound healing process. The actual extent to which any one growth factor or cytokine is essential for wound repair has not been determined.5

We did identify one exception to the above scheme. EndoForm Dermal Template derived from ovine forestomach, and included in FDA product code KGN, is an exception to the use of the term “management” of wounds and instead uses the term “treatment” in the indications for use (see Table 8). The wording of the indications for use of EndoForm is almost identical to the wording used for Integra™, MatriStem, Oasis^®^, Primatrix™, and Hyalomatrix^®^, but “treatment” is substituted for “management.” The reason for this difference is unclear.

### Key Question 2 For patients with chronic wounds (pressure ulcers, diabetic foot ulcers, venous leg ulcers, or arterial leg ulcers), are skin substitutes more effective than other wound care options (usual or standard care, or usual or standard care plus synthetic dressings, growth factors, skin grafts, or other treatments used as a comparison) in promoting wound healing for the following outcome measures

a. Percentage of completely closed/healed wounds
b. Time to complete wound closure
c. Wound reoccurrence
d. Wound infection
e. Need for amputation
f. Need for hospitalization (frequency and duration)
g. Return to baseline activities of daily living and function
h. Pain reduction
i. Exudate and odor reduction

Our searches identified 18 randomized controlled trials (RCTs) that met our inclusion criteria (see Table 5). Twelve studies examined diabetic foot ulcers, and six studies examined venous leg ulcers. Only seven skin substitute products were examined in the 18 RCTs. We identified only one study using skin substitutes to treat patients with pressure ulcers, but this study did not meet the inclusion criteria (see Table 20).

Table 5 List of included randomized controlled trials

Study | Comparison | Wound Type
DiDomenico et al. 2011^64^ | Apligraf vs. TheraSkin | DFU
Edmonds 2009^53^ | Apligraf vs. nonadherent dressing | DFU
Falanga et al. 1998^63^ | Apligraf with compression vs. compression therapy | Leg, Venous
Krishnamoorthy et al. 2003^55^ | Dermagraft plus multilayered compression bandage therapy (Profore™) vs. multilayered compression therapy | Leg, Venous
Marston et al. 2003^56^ | Dermagraft vs. saline-moistened gauze | DFU
Naughton et al. 1997^62^ | Dermagraft vs. saline-moistened gauze | DFU
Gentzkow et al. 1996^65^ | Dermagraft vs. saline-moistened gauze | DFU
Reyzelman et al. 2009^66^ | Graftjacket acellular matrix vs. moist wound therapy with alginates, foams, hydrocolloids, or hydrogels | DFU
Brigido 2006^59^ | Graftjacket acellular matrix vs. weekly debridement, Curasol wound hydrogel and gauze dressing | DFU
Veves et al. 2001^67^ | Graftskin vs. saline-moistened gauze alone | DFU
Uccioli et al. 2011^68^ | Hyalograft 3D autograft/LasersSkin vs. nonadherent paraffin gauze | DFU
Caravaggi et al. 2003^58^ | Hyalograft 3D autograft/LaserSkin vs. nonadherent paraffin gauze | DFU
Romanelli et al. 2010^57^ | Oasis Wound Matrix vs. a petrolatum-impregnated gauze | Leg, Mixed
Landsman et al. 2008^54^ | Oasis Wound Matrix vs. Dermagraft | DFU
Romanelli et al. 2007^60^ | Oasis Wound Matrix vs. Hyaloskin (contains hyaluronan) | Leg, Mixed
Mostow et al. 2005^69^ | Oasis Wound Matrix with compression vs. compression alone | Leg, Venous
Niezgoda et al. 2005^70^ | Oasis Wound Matrix vs. Regranex Gel (contains platelet-derived growth factor) | DFU
Kelechietal. 2011^61^ | Talymed poly-N-acetyl glucosamine (pGlcNAc) with compression vs. nonadherent absorptive primary dressing with compression | Leg, Venous

DFU: Diabetic foot ulcer

HYAFF: Benzyl esters of hyaluronic acid

Leg: Vascular leg ulcer

SOC: Standard of care

Outcomes reported in the included studies were primarily complete wound healing by 12 weeks (13 studies), time to complete wound healing (12 studies), complete wound healing after 12 weeks (9 studies), and wound infection (16 studies). Complete wound healing was defined in these studies as full epithelialization with no drainage, meaning that no exudate or scab was present. However only four of the studies (Edmonds 2009,53 Landsman et al. 2008,54 Krishnamoorthy et al. 2003,55 and Marston et al. 2003^56^) reported reassessment of wound healing within 2 weeks of wound closure. Eight studies used various followup methods that included biweekly, monthly, or every 3 month wound reassessment till the end of the study. Wound recurrence after 12 weeks was reported in seven studies. Six studies do not mention reassessment or planned followup to assessment the durability of wound closure. Other outcomes listed in Key Question 2 were not as frequently reported, and measures of function and activities of daily living were not reported in any study.

One of the 18 RCTs was considered to have an unclear risk of bias primarily because of poor reporting of methods (see Table 22 to Table 26), which limited the assessment. Eight studies were considered to have low risk of bias, and nine were considered to have moderate risk of bias. None of the studies reported blinding of wound assessment. Other areas of concern for study design and conduct were poor reporting of comorbidities and wound severity prior the start of treatment. Only seven of the 18 studies included in this report mention the use of a run-in period prior to enrolling patients in the study and only two studies reported wound severity prior to starting treatment.

The strength of the evidence base for evaluating complete wound healing of diabetic foot ulcers at 12 weeks was graded as low for the comparisons of Graftjacket vs. moist wound products, the comparison of Apligraf vs. a nonadherent dressing and for Graftskin vs. saline-moistened gauze. Each of these studies represented a multicenter trial with a low risk of bias for the outcome of complete wound healing. The outcome measure was direct and the results were precise. Although the evidence for the comparison of Dermagraft vs. saline-moistened gauze came from 3 studies including 530 patients and had a precise result of a direct outcome, we judged the strength of the evidence to be only low because the studies had a moderate risk of bias. The strength of the evidence for other comparisons for diabetic foot ulcers were graded insufficient, primarily because the overall risk of bias was moderate and/or the reported treatment effect (percentage increase in completely healed wounds) was imprecise.

Only two comparisons were judged to have low strength of evidence for complete wound healing of venous or mixed ulcers at 12 weeks. One compared Apligraf and compression to compression, and one compared Oasis Wound Matrix with compression to compression. In each case, the included study was a multicenter trial, had a low risk of bias and reported a precise and direct result. The other comparisons were from studies with moderate risk of bias and imprecise results; these were judged to have an insufficient strength of evidence grade.

A grade of low means we have low confidence that the evidence reflects the true effect of skin substitutes on complete wound healing, and we believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect. A grade of insufficient indicates that the available evidence does not support a conclusion regarding the comparison.

The applicability of the evidence is another important issue with the studies included in this report. The patients examined in these studies were of generally good health, under good glycemic control, and had adequate blood flow to the wound area to assist in the healing process. Among study design and other patient information of interest to this report, prior wound treatments were not reported in any of the studies and comorbidities were poorly reported. Because patients enrolled in these studies are in generally good health and free of infected wounds, medications that would impede wound healing, clinically significant medical conditions, significant peripheral vascular disease, malnutrition, and uncontrolled diabetes the applicability of the evidence to patients who are in poorer overall health is unclear.

Only 7 of the 57 skin substitute products identified for this report were examined in RCTs. Wound healing data from one group of skin substitutes cannot be extrapolated to other groups because of the difference in composition and healing properties. Similarly, data from studies of diabetic foot ulcers cannot be extrapolated to venous leg ulcers because of the differences in etiology and pathophysiology. Therefore, clinical evidence from RCTs demonstrating the efficacy of skin substitute products for treating chronic wounds is very limited.

In 12 of the included studies, treatment efficacy was judged by the number of wounds healed after 12 weeks of treatment. Two studies reported on wound healing at fewer than 12 weeks, one at 8 weeks,57 and one at 11 weeks.58 The remaining studies measured wound healing at 16 weeks,59,60 20 weeks,61 32 weeks,62 and 6 months63 (see Table 49 to Table 53). Recurrence rates varied widely across studies but were comparable between groups within studies. Other outcomes not directly related to wound healing, such as amputation, hospitalization, return to function, and pain relief, were poorly reported.

### Key Question 3 What type and frequency of adverse events are reported in the clinical literature for each of the FDA-regulated skin substitute products?

Cellulitis and osteomyelitis were reported in several studies. Many of the studies report adverse events but do not specify what they are.

## Conclusion

Our searches identified 57 skin substitute products (as identified in this report) available in the United States that are used to manage or treat chronic wounds and are regulated by FDA. Based on the FDA regulations that govern each product we identified and on the origin and composite of the products, skin substitutes can be organized into four groups: human-derived products regulated as HCT/Ps, human- and human/animal-derived products regulated through PMA or HDE, animal-derived products regulated under the 510(k) process, and synthetic products regulated under the 510(k) process. Human tissue can be obtained from human donors, processed, and used in exactly the same role in the recipient, such as a dermal replacement to be placed in a wound as a skin substitute (regulated as HCT/Ps). These products may be regulated under the Biologics License Application (BLA) (under the PHS Act) or PMA/HDE (under the FD&C Act), depending on their composition and primary mode of action. Other skin substitutes are derived only from animal tissue or biosynthetic materials and are regulated under the 510(k) process.

One of this report's goals was to begin to characterize the state of the evidence on skin substitutes as wound care products for chronic wounds. For this report, we sought to determine the number of RCTs of these products and to assess the efficacy of skin substitutes in the trials. The following key points were noted about the strength of this evidence and its applicability:

- Eighteen RCTs examining only seven of the skin substitute products identified for this report met the inclusion criteria. Twelve of the studies examined diabetic foot ulcers, and six studies examined vascular leg ulcers.
- No studies of pressure ulcers met our inclusion criteria; only one RCT of pressure ulcers was identified.
- Of the included studies, none had a high risk of bias and one had an unclear risk of bias, while the others were divided between low (eight studies) and moderate (nine studies) risk of bias.
- No studies reported blinding of the person assessing wound healing
- All the studies in the evidence base reported some benefit of skin substitutes over the control treatments when number of wounds completely healed was measured between 8 and 16 weeks but the reported results varied widely across studies.
- The strength of the evidence base for evaluating complete wound healing of diabetic foot ulcers at 12 weeks was graded as low for the comparisons of Graftjacket vs. moist wound products, the comparison of Apligraf vs. a nonadherent dressing, for Graftskin vs. saline-moistened gauze, and for Dermagraft vs. saline-moistened gauze. The strength of the evidence for other comparisons for diabetic foot ulcers were graded insufficient, primarily because the overall risk of bias was moderate and/or the reported treatment effect (percentage increase in completely healed wounds) was imprecise. A grade of low means we have low confidence that the evidence reflects the true effect of the skin substitute on complete wound healing as compared to another intervention, and we believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Two comparisons were judged to have low strength of evidence for complete wound healing of venous or mixed ulcers at 12 weeks - one comparing Apligraf and compression to compression, and one comparing Oasis Wound Matrix with compression to compression. In each case, the included study was a multicenter trial, had a low risk of bias and reported a precise and direct result. The other comparisons were from studies with moderate risk of bias and imprecise results; these were judged to have an insufficient strength of evidence grade.
- Data on wound recurrence was reported in only seven studies where followup was between 6 and 14 months. Recurrence rates varied widely across studies but were comparable between groups within studies.
- Only generally healthy patients were enrolled in studies. Patients with infected wounds, who used medications that could impede wound healing, had clinically significant medical conditions, significant peripheral vascular disease, malnutrition, or uncontrolled diabetes were excluded.
- No clinical efficacy data from RCTs are available for the large majority of the skin substitute products identified in this report.
- Overall applicability of the evidence base is limited to a small number of skin substitutes examining diabetic foot ulcers and vascular leg ulcers and to patients in generally good health.
- Various features of study design and conduct as pointed out in this report could be improved in future wound care studies to ensure better study quality and low potential for bias.

Our evaluation of the clinical literature indicates that studies comparing the efficacy of skin substitutes to alternative wound care approaches are limited in number, apply mainly to generally healthy patients, and examine only a small portion of the skin substitute products available in the United States.

The results of the available studies cannot be extended to other skin substitute products because of differences in active components in the various products. Additionally, the results from studies of diabetic foot ulcers do not extrapolate to studies of vascular leg ulcers or pressure ulcers because of differences in wound pathophysiology and etiology. The studies that are available are also not generalizable to the broader patient population that is not as healthy as the patients in these studies. Also missing from this evidence base were studies that compared the various types of skin substitute products. Only two of the 18 studies compared two skin substitute products (Oasis versus Hyaloskin and Apligraf versus TheraSkin). How a human dermal substitute such as Graftjacket compares with a human derived skin substitute such as Dermagraft when treating a diabetic foot ulcer or a vascular leg ulcer is unknown. Such comparisons could be useful to clinicians trying to decide which wound treatment products to use. Additional studies in this area of wound care would be helpful to provide treatment data for many of the other skin substitute products, to allow better comparisons between wound care products, and to provide better information on wound recurrence when using skin substitute products.

## Abbreviations and Acronyms

ABI: Ankle brachial index
AHRQ: Agency for Healthcare Research and Quality
CFR: Code of Federal Regulations
CMS: U.S. Centers for Medicare and Medicaid Services
DFU: Diabetic foot ulcer
FDA: U.S. Food and Drug Administration
HCT/Ps: Human cells, tissues, and cellular and tissue-based products
HDE: Humanitarian device exemption
HUD: Humanitarian Use Device
HYAFF: Benzyl ester of hyaluronic acid
PHS: Public Health Service
PMA: Premarket Approval
RCT: Randomized controlled trial
SOC: Standard of care