# Skin Substitute Products Considered in This Report

Products derived from human donor tissue, minimally processed:

- AlloDerm Regenerative Tissue Matrix
- Allopatch HD™
- Alloskin™
- Cymetra^®^ Micronized AlloDerm
- Dermacell ^®^ and Arthroflex^®^
- Flex HD^®^
- GammaGraft^®^
- Graftjacket^®^ Regenerative Tissue Matrix
- Matrix HD™
- Memoderm™
- Puros^®^ Dermis
- Repliform^®^
- TheraSkin^®^

Products derived from living human and/or animal tissues and cells:

- Apligraf^®^/Graftskin
- Dermagraft^®^

Acellular animal-derived products:

- ACell UBM Hydrated Wound Dressing
- ACell UBM Lyophilized Wound Dressing
- Aongen™ Collagen Matrix
- Atlas Wound Matrix
- Avagen Wound Dressing
- Collagen Sponge (Innocoll)
- Collagen Wound Dressing (Oasis Research)
- Collaguard^®^
- CollaSorb™
- CollaWound™
- Collexa^®^
- Collieva^®^
- Coreleader Colla-Pad
- Dermadapt™ Wound Dressing
- DressSkin
- E-Z Derm
- EndoForm Dermal Template™
- Excellagen
- FortaDerm™ Wound Dressing
- HA Absorbent Wound Dressing
- Helicoll
- Integra™/Bilayer Matrix Wound Dressing
- Integra™ Flowable Wound Matrix
- LTM Wound Dressing
- MatriStem
- MatriStem^®^ Wound Matrix
- Matrix Collagen Wound Dressing
- Medline Collagen Wound Dressing
- Oasis^®^
- Primatrix™
- Primatrix™ Dermal Repair Scaffold
- SIS Wound Dressing II
- SS Matrix™
- Stimulen™ Collagen
- TheraForm™ Standard/Sheet
- Unite^®^ Biomatrix
- Unite™Biomatrix

Biosynthetic products:

- Hyalomatrix^®^ (Laserskin^®^)
- Hyalomatrix^®^
- Jaloskin^®^
- Suprathel^®^
- Talymed^®^