# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Vickie R. Driver, M.S., D.P.M., F.A.C.F.A.S.
  Associate Professor of Surgery
  Director, Clinical Research Limb Preservation, Wound Healing
  Director, Research Fellowship and International Scholars Program
  Boston University Medical Campus and Boston University School of Medicine
  Boston, Massachusetts
- Mary E. Ritchey, Ph.D.
  Associate Division Director
  FDA/CDRH/Office of Surveillance and Biometrics
  Food and Drug Administration
  Silver Spring, MD