# Discussion and Conclusions

Our searches identified 57 skin substitute products (as defined in this report) available in the United States that are used to manage or treat chronic wounds and regulated by FDA. Based on FDA regulations that govern each product we identified and on the origin and composite of the products, skin substitutes can be organized into four groups: human-derived products regulated as HCT/Ps, human- and human/animal-derived products regulated through PMA or humanitarian device exemption (HDE), animal-derived products regulated under the 510(k) process, and synthetic products regulated under the 510(k) process. Human tissue can be obtained from human donors, processed, and used exactly in the same role in the recipient, such as a dermal replacement to be placed in a wound as a skin substitute (regulated as HCT/Ps). Human tissue and cells may also be used as a source of cells for culturing to produce cellular-derived material for wound healing. These products may be regulated under the BLA or PMA/HDE processes, depending on their composition and primary mode of action. Other skin substitutes are derived only from animal tissue or biosynthetic materials and are regulated under the 510(k) process.

The skin substitutes listed in this report cover a wide variety of components, from cellular to acellular, that may provide important elements in treating or managing chronic wounds. The products regulated under the 510(k) process were generally acellular and contained collagen as the primary component. These products are indicated for managing partial- to full-thickness wounds including pressure ulcers, venous ulcers, and diabetic ulcers and may be used as first-line treatments. In contrast, products such as Apligraf and Dermagraft, regulated under PMA, that contain a human cellular component combined with a acellular component are indicated for chronic wounds that have not healed for more than 30 days. Therefore, the wounds treated by Apligraf or Dermagraft have not responded to other treatments such as gauze or to the products regulated under the 510(k) process. Because of the requirements placed on the PMA process, products such as Apligraf and Dermagraft also have more clinical evidence from RCTs supporting their efficacy compared with products regulated under the 510(k) process. Products using the 510(k) process rely on similarity to predicate products to support their efficacy.

We identified some products not regulated through the PMA process that were examined in RCTs. These included TheraSkin (compared with Apligraf), Graftjacket (compared with various wound dressings), Hyalograft 3D/Laserskin (compared with gauze), Oasis Wound Matrix (compared with gauze and other wound dressings), and Talymed (compared with gauze). When assessing risk of bias of the RCTs included in this report and the strength of the evidence base, no special consideration was given to whether a product was regulated under PMA or 510(k).

One of the goals of this report was to begin to characterize the state of the evidence base on skin substitutes as wound care products for chronic wounds. For this report, we sought to determine the number of RCTs of these products and to assess the ability of skin substitutes to promote wound healing in these trials. Eighteen RCTs, examining only seven of the skin substitute products identified for this report, met the inclusion criteria. Twelve of the studies examined diabetic foot ulcers and six studies examined venous and/or arterial leg ulcers. No studies of pressure ulcers met our inclusion criteria; only one RCT of pressure ulcers was identified.

Very few of the skin substitute products identified in this report have been examined in RCTs. Comparisons with other alternatives to usual wound care were also limited. Saline-moistened gauze or nonadherent paraffin gauze was the most used comparison in trials examining the treatment of diabetic foot ulcers.

Various organizations interested in wound care have made recommendations for the proper design and conduct of studies evaluating wound treatments.10,106,108,113 These recommendations coupled with recommendations on how to assess risk of bias in a study are the basis for the questions used to assess study quality in this report. Blinding of the individuals assessing wound outcomes was suggested by all of these organizations. Our review of the methods used in the studies included in this report indicates that no study actually blinded wound assessors to treatment assignment. While complete wound closure is an objective outcome with less need for blinding, other less objective outcomes such as time to 50 percent wound closure or rate of wound reduction should be assessed in a blinded fashion. While we judged eight studies to have low potential for bias and nine studies to have moderate potential for bias when assessing complete wound closure, the assessment of other wound outcomes would likely have higher potential for bias. Various features of study design and conduct as pointed out in this report could be improved in future wound care studies to ensure better study quality and low potential for bias.

The strength of the evidence base for evaluating complete wound healing of diabetic foot ulcers at 12 weeks was graded as low for the comparisons of Graftjacket vs. moist wound products,66 the comparison of Apligraf vs. a nonadherent dressing,63 and for Graftskin vs. saline-moistened gauze.67 Each of these studies represented a multicenter trial with a low risk of bias for the outcome of complete wound healing. The outcome measure was direct and the results were precise. Although the evidence for the comparison of Dermagraft vs. saline-moistened gauze came from 3 studies including 530 patients and had a precise result of a direct outcome, we judged the strength of the evidence to be only low because the studies had a moderate risk of bias.56,62,65 The strength of the evidence for other comparisons for diabetic foot ulcers were graded insufficient, primarily because the overall risk of bias was moderate and/or the reported treatment effect (percentage increase in completely healed wounds) was imprecise.

Only two comparisons were judged to have low strength of evidence for complete wound healing of venous or mixed ulcers at 12 weeks. One compared Apligraf and compression to compression,63 and one compared Oasis Wound Matrix with compression to compression.69 In each case, the included study was a multicenter trial, had a low risk of bias and reported a precise and direct result. The other comparisons were from studies with moderate risk of bias and imprecise results; these were judged to have an insufficient strength of evidence grade.

A grade of low means we have low confidence that the evidence reflects the true effect of skin substitutes on complete wound healing, and we believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect. A grade of insufficient indicates that the available evidence does not support a conclusion regarding the comparison.

Applicability of the evidence base to address important questions about the effectiveness of skin substitutes for treating chronic wounds in typical populations was limited. The overall applicability of the evidence base is limited to a small number of skin substitute products examining diabetic foot ulcers and venous and/or arterial leg ulcers and to patients in generally good health. Although these results are consistent in showing a benefit when using skin substitutes and suggest that skin substitutes could be used in treating diabetic foot ulcers and venous leg ulcers, the patients enrolled in these studies were in generally good health and free of infected wounds, medications that would impede wound healing, clinically significant medical conditions, significant peripheral vascular disease, malnutrition, or uncontrolled diabetes. The results of these studies may not easily translate to everyday clinical situations. The expected population with chronic wounds is likely to have these conditions; therefore, the results reported in studies without these patients may not extrapolate well. The applicability of the findings to sicker patients may be limited.

The results of the available studies cannot be extended to other skin substitute products because of differences in active components in the various products. Additionally, the results from studies of diabetic foot ulcers do not extrapolate to studies of venous or arterial leg ulcers because of differences in pathophysiology and etiology. Therefore, no clinical efficacy data from RCTs are available for the large majority of the skin substitute products identified in this report. The studies that are available may not be generalizable to a broader patient population that is not as healthy as the patients in these studies.

Also missing from this evidence base were studies that compared the various types of skin substitute products. Only two of the 18 studies compared two skin substitute products (Oasis versus Hyaloskin and Apligraf versus TheraSkin). How a human dermal substitute such as Graftjacket compares with a human derived skin substitute such as Dermagraft when treating a diabetic foot ulcer or a vascular leg ulcer is unknown. Such comparisons could be useful to clinicians trying to decide which wound treatment products to use. Additional studies in this area of wound care would be helpful to provide treatment data for many of the other skin substitute products, to allow better comparisons between wound care products, and to provide better information on wound recurrence when using skin substitute products.