# Background

The Center for Medicare Management at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the ECRI Institute Evidence-based Practice Center (EPC) under Contract Number: HHSA 290-2007-10063.

A wide variety of wound care products are available for clinicians to choose from when treating chronic wounds. Many of these products are said to mimic or substitute for some aspect of the skin's structure and function to promote healing and wound closure. The materials used to produce these products may be derived from human or animal tissue and may undergo extensive or minimal processing to make the finished product. The extent of processing and the source of the material used in the product also determines what regulatory pathway may be required before the product can be marketed. CMS requested this report on the types of wound care products that are commonly referred to as “skin substitutes” and on the regulatory pathways required for the different types of products. For this report, we have not created a definition for a skin substitute product. Instead we used the products listed under CMS codes Q4101 to Q4122 as a starting point and looked for similar products listed in the U.S. Food and Drug Administration (FDA) product codes to generate a list of products. We included only those products indicated for chronic wounds. We note that FDA does not refer to any product or class of products as “skin substitutes,” and we are not proposing an official classification system.

In addition to identification of the products, a second objective of this review was to begin to characterize the state of the evidence base on skin substitutes as wound care products. To address this objective, we sought to determine the number of RCTs of these products and to assess the efficacy of skin substitutes under the conditions presented in the trials. Systematically reviewing and analyzing all the clinical research on skin substitutes is beyond the scope of this report.

This report specifically examined the use of skin substitutes for treating the following chronic wound types: diabetic foot ulcers, pressure ulcers, and vascular ulcers (including venous ulcers and arterial ulcers). Treatment of burn wounds with skin substitutes is outside the scope of this report.

## Normal Healthy Skin

As the interface between the environment and body, the skin has several distinct functions. It protects the underlying tissues from abrasions, the entry of microbes, unwanted water loss, and ultraviolet light damage. Tactile sensations of touch, pressure, and vibration, thermal sensations of heat and cold, and pain sensations all originate in the skin's nervous system. The body's thermoregulation relies on the skin's ability to sweat and to control the flow of blood to the skin to increase or decrease heat loss. The skin's functions are performed by three distinct tissue layers: a thin outer layer of cells called the epidermis, a thicker middle layer of connective tissue called the dermis, and an inner, subcutaneous layer. The outer layers of the epidermis are composed of flattened, cornified dead keratinocytes that form a barrier to water loss and microbe entry. These cells are derived from a basal layer of constantly dividing keratinocytes that lies next to the dermis. The epidermis does not contain nerves or blood vessels and obtains water and nutrients through diffusion from the dermis. The dermis is composed mostly of collagen fibers and some elastic fibers both produced by fibroblasts and, along with water and large proteoglycan molecules, makes up the extracellular matrix. This layer of the skin provides mechanical strength and a substrate for water and nutrient diffusion; it contains blood vessels, nerves, and cells involved in immune function, growth, and repair. The dermis also contains sweat glands, oil glands, and hair follicles. The subcutaneous layer is composed of adipocytes that form a thick layer of adipose tissue.1

## Chronic Wounds

Wounds are breaches in the structure of the skin that compromise skin function. Superficial wounds such as abrasions affect mainly the epidermis and are quickly healed by growth of new keratinocytes to cover the damaged skin. Partial-thickness skin loss involves the epidermis and dermis and requires more extensive healing, especially if the wound is large. Full-thickness skin loss involves penetration through the epidermis and dermis into the subcutaneous tissue and may expose muscle and bone.

Chronic wounds have not completed the process of healing (restoring tissue loss and restoring skin function) in the expected time frame, usually within 30 days;2 have not responded to initial treatment; or persist despite appropriate care.3 These wounds usually do not close without interventions and are sometimes resistant to healing interventions. Diabetic foot ulcers, pressure ulcers or “bed sores,” vascular ulcers, and complications of surgically created sternal wounds commonly become chronic wounds because their etiologies impede healing, and they persist without proper medical care. For this review, we consider chronic wounds to be wounds present for more than 30 days and acute wounds to be those present for fewer than 30 days. Diabetic foot ulcers, venous leg ulcers, and pressure ulcers are the chronic wounds most often treated with a skin substitute.

Chronic wounds of the lower extremity (from hips to feet) affect about 6 million people in the United States, especially the elderly.3

### Diabetic Foot Ulcers

Patients with diabetes often develop foot ulcers due to atherosclerosis that impedes blood flow to the extremities and peripheral neuropathy that prevents the sensation of discomfort associated with mechanical stress on or injury to the feet. Each of these complications of diabetes increases the probability of ulcer formation on pressure-bearing areas of the feet. Neuropathy is present in 60 percent to 70 percent of patients with diabetic foot ulcers, with 15 percent to 20 percent of patients having a combination of neuropathy and vascular problems. Patients with diabetic neuropathy are often not aware of repeated mechanical trauma, and ulcers commonly form under the foot. An estimated 16 million Americans are known to have diabetes. Among patients with diabetes, 15 percent develop a foot ulcer, and 12 percent to 24 percent of individuals with a foot ulcer require amputation.71

Diabetic foot ulcers may be classified using the Wagner Classification System.72 This system is based mainly on wound depth and consists of six wound grades. Grade 0 foot ulcers have intact skin with bony deformities or dry keratinized skin that increases the potential for ulceration, grade 1 involves ulceration of the dermis, grade 2 has ulceration involving tendons and joints, grade 3 extends to the bone and causes osteomyelitis, grade 4 shows localized gangrene, and grade 5 has gangrene involving a major portion of the foot.73 Improved foot care will often help in healing foot ulcers caused by diabetic neuropathy, but ischemic foot ulcers are often difficult to heal unless the underlying vascular problems are corrected.71,74

The major health consequences of diabetic foot ulcers are wound infections, osteomyelitis, and subsequent amputation. Individuals with severe diabetic foot ulcers may be at risk of dying due to concomitant arteriosclerotic disease involving the coronary or renal arteries. Managing diabetic foot ulcers requires appropriate therapeutic footwear, a wound dressing that provides a moist environment, débridement when necessary, antibiotic therapy if osteomyelitis or cellulitis is present, and evaluation and correction of peripheral arterial insufficiency.71,75

### Pressure Ulcers

Pressure ulcers, also called “decubitus ulcers,” “bed sores,” or “pressure sores,” are defined as lesions caused by unrelieved pressure or shear resulting in damage of underlying tissue.76 These wounds often occur over bony prominences. Prolonged pressure causes ischemia, which leads to tissue necrosis that typically first occurs in the tissue closest to the bone. Ischemic cell death produces inflammation that results in blood clotting, platelet aggregation, immune complex formation, and the accumulation of inflammatory cells. Patients who are chairbound or bedridden are at increased risk for developing pressure ulcers. The following factors further increase their risk of pressure ulcer development: advanced age, impaired ability to reposition themselves, friction, decreased sensory perception, impaired nutrition, and excessive exposure to moisture (i.e., incontinence, excessive perspiration, wound drainage).77 The exact incidence and prevalence of pressure ulcers are unclear. Reports of pressure ulcer incidence vary widely, from 0.4 percent to 38.0 percent in acute care, from 2.2 percent to 24.0 percent in long-term care, and from 0 percent to 17 percent in home care.78

Pressure ulcers are classified in stages according to the degree of tissue damage. Stage 1 pressure ulcers are distinguished by non-blanchable redness of intact skin, stage 2 by superficial skin loss (partial-thickness skin loss of the epidermis and dermis), stage 3 by subcutaneous tissue loss (full-thickness skin loss penetrating through the epidermis and dermis into the subcutaneous tissue), and stage 4 by tissue loss that extends into the underlying muscle, tendon, or bone.77 The health consequences of pressure ulcers include local infection, sepsis, osteomyelitis, and pain.79 Local infection of pressure wounds is common and is usually controlled by débridement and antibiotics. Osteomyelitis is a risk in pressure ulcer patients because these ulcers develop over bony prominences.

Treatment of pressure ulcers centers on the following interventions: managing tissue load (i.e., pressure, friction, shearing), nutritional support, ulcer care, and managing bacterial colonization and infection.77 Usual care for pressure ulcers depends on the ulcer stage and usually includes pressure relief and skin protection to prevent progression of the ulcer to advanced stages, débridement of necrotic tissue in stage 3 and 4 ulcers, wound cleansing, and dressings that promote a moist wound environment and absorb exudate.

### Vascular Leg Ulcers

Vascular leg ulcers are the result of chronic venous insufficiency (venous leg ulcers, 80 percent to 95 percent of vascular ulcers), or arterial insufficiency (arterial leg ulcers, 5 percent to 10 percent). Between 10 percent and 35 percent of the U.S. population has some type of venous disease, and lower extremity skin ulcers are reported in 1 percent to 22 percent of individuals older than age 60.^80^

The underlying problem in venous leg ulcers is venous hypertension in the deep and superficial venous system caused by incompetent valves and the incomplete removal of blood from the venous system. The disorder may be due to a previous blood clot that destroys the valves, a comorbid medical problem (arterial disease), or a hereditary absence of the valves in the venous system. The venous hypertension dilates capillaries and increases capillary filtration, causing edema followed by subcutaneous tissue destruction and ulcer formation. Wounds caused by venous insufficiency are hard to heal and often recur.80

Venous leg ulcers, if left untreated, may remain for years and lead to depression, anxiety, reduced activity, and a reduction in the patient's quality of life.81,82 Pain may be experienced by as many as 80 percent of venous leg ulcer patients.83 Edema of the leg is frequently associated with venous leg ulcers. The edema may be the result of the venous insufficiency, inflammation, compromised lymphatic system associated with the wound, or systemic disorders such as heart failure.84 Contact dermatitis is also common in patients with venous leg ulcers, and allergic reactions to wound dressings, topical ointments, and bandage material may hinder wound healing.

Treating venous leg ulcers involves cleaning and protecting the wound, facilitating the healing process, and providing hemodynamic support to control the underlying disorder responsible for the ulcer.80 Wound cleaning can be performed with sterile or nonsterile water or saline and gauze compresses to remove loose slough and eschar from the wound. When necessary, débridement can be performed with application of enzymes or sharp débridement procedures (forceps, scissors, lasers) before applying the dressing and compression bandages. Hemodynamic support is provided by compression bandages that counter the venous hypertension responsible for ulcer development. Compression bandages are a vital part of treating venous leg ulcers. Therapeutic compression stockings with compression of 30-40 mm Hg will counteract the capillary pressure in the tissues. Restoring blood flow through the skin reduces edema, increases oxygen and carbon dioxide exchange, and increases nutrient flow into the tissues. Compression may be applied using a single-component (a stocking or single type of bandage) or a multi-component system using several layers of material. A systematic review from 2009 examined the evidence for compression treatment of venous leg ulcers. According to the authors, venous ulcers heal more rapidly with compression than without and multi-component systems achieve better healing outcomes than single-component compression.85

Arterial ulcers are caused by blood-flow restriction in an artery, resulting in ischemia and ulcer development.86 Necrotic tissue with minimum exudate is common in this type of ulcer. Treatment is based on restoring perfusion to the affected tissue either through surgery or medication. Compression bandages are not typically used to treat arterial ulcers because they may increase the ischemia and the risk of amputation.87

## Phases of Normal Wound Healing

Skin wounds heal in three distinct phases: the hemostatic or inflammation phase, the proliferative phase, and the maturation or remodeling phase.88 The inflammatory phase begins with tissue damage that often results in the release of blood and the formation of a fibrin clot. Platelets release cytokines and growth factors that attract inflammatory cells (neutrophils, eosinophils, and monocytes) and initiate the inflammatory response. The inflammatory phase also initiates cellular and vascular responses that clear dead tissue, bacteria, and foreign material from the wound. Vasodilation and increased capillary permeability around the wound allow serum proteins and leukocytes to infiltrate the area and begin the healing process. Macrophages appear within 48 hours and aggressively remove dead tissue and bacteria. Activated macrophages secrete cytokines that attract fibroblasts to the wound. The clot forms a temporary shield over the wound and provides a structure through which inflammatory cells, fibroblasts, and vascular endothelial cells move to form granulation tissue. The inflammatory phase lasts about 2–5 days.74,89-91

Fibroblasts appear in the wound within 2–3 days and mark the beginning of the fibroblast proliferation phase. This phase may last up to three weeks. Fibroblasts produce and extrude collagen, which then forms into fibers that provide tensile strength to the wound. Fibroblasts also secrete a variety of growth factors that guide the formation of the new extracellular matrix. New blood vessels advance into the wound along with the fibroblasts to satisfy the metabolic needs of collagen formation. The new blood vessels, collagen, and proteoglycan ground substance form the granulation tissue. Granulation tissue fills a deep wound during the early phases of the healing process. Its formation is a key part of wound healing. Myofibroblasts within the granulation tissue contract, pull the wound edges together, and reduce the size of the wound. Re-epithelialization occurs during the fibroblast proliferative phase as epithelial cells (keratinocytes) proliferate and migrate over the granulation tissue. The new epithelial cells provide a barrier to bacteria and prevent fluid loss. In wounds with a large surface, epithelialization is enhanced by a moist environment. Dry wounds with a large dry eschar (commonly referred to as a “scab”) impede epithelial cell migration.74,89-91

Growth factors and cytokines released into a wound play various roles in orchestrating the chain of events that results in restoration of the skin's barrier function and mechanical integrity. Growth factors are polypeptides that interact with cell receptors to signal migration, proliferation, differentiation, and secretion of proteins such as collagen or additional growth factors. Platelet-derived growth factors (PDGFs) begin the healing process and start the interaction between cells and the extracellular matrix in the wound. Platelets also release transforming growth factor (TGF)-α and TGF-β, which increase cell proliferation. Activated monocytes and macrophages produce additional growth factors that activate angiogenesis. PDGF stimulates fibroblast proliferation and along with TGF-β stimulates fibroblasts to produce collagen, hyaluronic acid, matrix metalloproteinases, and additional proteins that build the extracellular matrix. Growth factors present in the newly formed granulation tissue stimulate the proliferation of keratinocytes at the wound margins. While PDGF and TGF are important elements in the healing process they represent only a small portion of all of the factors involved in wound healing. Vascular endothelial growth factor, epidermal growth factor, fibroblast growth factor, connective tissue growth factor, and other factors have roles in different stages of wound healing. Understanding of the interaction between these growth factors, cells, and the extracellular matrix in chronic wounds is far from complete. Currently, the use of growth factors to promote wound healing has a limited role. Successful use of growth factors will depend on a better understanding of when each growth factor or combination of factors should be used, how to deliver the growth factors to the wound, and what dosages will ensure proper wound healing.92-94

By three weeks after injury, collagen synthesis and degradation are in homeostasis, and wound remodeling begins. Maturation of the wound takes place with increasing levels of type I collagen, compared with type III collagen, and thickening of the collagen fibers. The new tissue formed in the wound progressively increases in tensile strength. This process may continue for up to two years.74,89-91

The wound healing process should result in the restoration of skin structure and function. Lazarus et al.2 has proposed that healed wounds be placed in one of three categories: ideally healed, acceptably healed, and minimally healed. An ideally healed wound has returned to “normal anatomic structure, function, and appearance that includes a fully differentiated and organized dermis and epidermis with intact barrier function.” An acceptably healed wound has “epithelialization capable of sustaining functional integrity during activities of daily living.” A minimally healed wound has achieved “restoration of epithelial coverage that does not establish a sustained functional result and may recur.”2

## Skin Substitutes

Skin substitutes were developed as an alternative to skin grafts, especially for burn patients. Autologous tissue grafting is an invasive and painful procedure, and often the extent of damaged skin is too large to be covered by autologous tissue graft alone. Tissue engineered skin substitutes and cultured skin cells were developed during the 1980s. Skin substitutes are now primarily used in treating chronic wounds rather than for burns, in part because chronic wounds are far more common than burn wounds.4

A true “skin substitute” would act like an autologous skin graft in adhering to the wound bed while providing the physiological and mechanical functions of normal skin.4 The skin substitutes included in this report contain various combinations of cellular and acellular components intended to stimulate the host to regenerate lost tissue and replace the wound with functional skin. Presumably, successful healing during management with these products would also require maintenance of a moist wound environment and other procedures thought to promote healing. These include removal of exudate and necrotic tissue, infection control, nutritional support, pressure avoidance (e.g., off-loading for diabetic foot ulcers and pressure ulcers) and edema control (e.g., compression for venous leg ulcers).5

Dieckmann et al. have suggested that skin substitutes can be divided into two broad categories: biomaterial and cellular.5 Biomaterial skin substitutes do not contain cells (acellular) and are derived from natural or synthetic sources. Natural sources include human cadaveric skin processed to remove the cellular components and retain the structural proteins of the dermis and collagen matrix obtained from bovine and porcine sources. Synthetic sources include degradable polymers such as polylactide and polyglycolide. Whether natural or synthetic, the biomaterial provides an extracellular matrix that allows for infiltration of surrounding cells. Cellular skin substitutes are distinguished by their origin: xenogeneic (from nonhuman species), autologous (from the patient), and allogenic (from another human). Keratinocytes and fibroblasts obtained from these sources are cultured in vitro to produce the cellular material used to make the substitute. However, the classification of skin substitutes into either biomaterial or cellular is not completely accurate since the two are combined into several wound care products (see Table 7).

## Usual Care for Chronic Wounds

Several requirements are necessary for proper and rapid healing of an open wound. During healing, either the edges of the wound seal back together (healing by “primary intention”) or granulation tissue must form to fill the wound bed (healing by “secondary intention”). Most importantly, the wound must remain moist because new epidermal cells will only travel across moist surfaces. Bacterial infection must be controlled and any fluids should be removed from the wound site while appropriate moisture is maintained. Additionally, contributing factors to wound occurrence should be eliminated or minimized if elimination is not possible. Bedridden patients may need special support surfaces and protein-calorie malnutrition and vitamin deficiencies should be corrected. Inadequate blood flow to the site of the wound should be corrected if possible, and drugs known to impede wound healing should be adjusted.89

Usual care for established chronic wounds incorporates common principles mentioned above that apply to managing all wound types. Clinicians remove necrotic tissue through débridement (achieved through sharp débridement using forceps and scissors, autolytic débridement by endogenous enzymes present in the wound, or application of exogenous enzymes in commercially available wound care products), maintain moisture balance by selecting the proper wound dressing to control exudate, and take measures to prevent or treat wound infections and to correct ischemia in the wound area. For venous leg ulcers, some form of compression is part of usual care. For diabetic foot ulcers, some form of off-loading is part of usual care. However, the methods for achieving each of these wound management principles varies among clinical practice guidelines and clinical studies.10,95

Wound dressings used as usual care show considerable variability among clinical studies. A systematic review commissioned by the AHRQ Technology Assessment Program found that among 43 RCTs examining the treatment of diabetic foot ulcers, 51 percent used saline wet-to-dry dressing as the control while 14 percent used a hydrocolloid dressing. The number of dressing changes per day also varied. Among 66 RCTs of venous leg ulcers, saline wet-to-dry was the control dressing in only 3 studies while an occlusive dressing such as hydrocolloid was used in 25 studies. Other control dressings used in the venous leg ulcers studies included the Unna boot, dry gauze, Vaseline gauze, or ointment. Venous ulcer dressings were changed less frequently than diabetic foot dressings, most often once or twice weekly.95

Chronic wounds are often treated with saline-moistened cotton gauze (wet-to-moist). Gauze dressings are moderately absorptive, easily available, and inexpensive. Saline-moistened gauze dressings can maintain a moist wound environment provided they are kept continuously moist until the dressing is removed. Therefore, wet-to-moist gauze dressings require close maintenance and added nursing time. The removal of a wet-to-moist dressing that has been allowed to dry may reinjure the wound by removing granulation tissue and lead to delayed wound healing. The removal of dried gauze dressings also causes the patient considerable pain, impedes healing, and increases the risk of infection. While gauze dressings are much less expensive per dressing than modern synthetic dressings, the increase in labor costs and ancillary supplies such as gloves and biohazardous waste disposal increase the total cost of care. The drawbacks of saline-moistened gauze dressings have been reviewed elsewhere.96

The phrase “standard of care” was commonly used in the studies included in this report in reference to the wound care used in the control group or the base wound care to which a skin substitute was added (see Appendix C for descriptions of control group wound care). However, as described above, “usual care” or “standard of care” does not describe an agreed-upon set of procedures to be used when treating chronic wounds. In the evidence tables describing the wound care received in each study in this report, we have separated the description into three parts: the skin substitute, the control dressing, and the ancillary wound treatment. The Ancillary Wound Treatment column describes the usual care or standard care received by all patients.

### Skin Grafts

Skin grafts are used in treating venous leg ulcers,97 diabetic foot ulcers, and burn wounds.65,97 Skin grafts are believed to assist wound healing by providing dermal collagen, growth factors, and biological occlusion and protection of the wound. Skin grafts are usually taken from a portion of intact skin of the same individual (autograft), but may be obtained by human skin donors (allograft). Skin grafts may be used in later stages of wound healing after the wound has established sufficient granulation tissue to support the graft. A recent Cochrane Review points out that insufficient evidence from RCTs was available to indicate whether skin grafting increased venous ulcer healing.98

### Wound Dressings

Dressings are selected based on the characteristics of the wound at any given point during the healing process.89 Wounds that produce exudate need an absorptive dressing (hydrocolloid, foam, alginate, hydrofiber) and dry wounds need a dressing that provides hydration (hydrogel). The type of dressing used will change as the wound goes through the phases of healing. Wound dressings that inhibit the loss of water vapor from the wound, thereby creating a moist environment, promote wound healing. Moist wound environments promote epithelialization and healing. Besides creating a moist wound environment, ideal dressings perform the following functions: remove excess exudates and toxic components, allow gaseous exchange, provide thermal insulation, and protect against secondary infection. A wide variety of wound dressings is available.99-102 Some of the unique features of each are described below.

The following dressings may be used on chronic or acute wounds depending on the nature of the wound.

- Low or nonadherent dressings are inexpensive and allow wound exudate to pass through into a secondary dressing while helping to maintain a moist wound environment. These dressings are specially designed to reduce adherence to the wound bed. Nonadherent dressings are made from open weave cloth soaked in paraffin, textiles, or multilayered or perforated plastic films. This type of dressing is suitable for flat, shallow wounds with low exudate such as a venous leg ulcer.
- Hydrocolloid dressings are composed of adhesive, absorbent, and elastomeric components. Carboxymethylcellulose is the most common absorptive ingredient. They are permeable to moisture vapor, but not to water. Additionally, they facilitate autolytic débridement, are self-adhesive, mold well, provide light-to-moderate exudate absorption, and can be left in place for several days, minimizing skin trauma and disruption of the healing process. They are intended for use on light-to-moderate exuding, acute or chronic partial- or full-thickness wounds but are not intended for use on infected wounds. Upon sustained contact with wound fluid, the hydrocolloid forms a gel.
- Foam dressings vary widely in composition and construction. They consist of a polymer, often polyurethane, with small, open cells that are able to hold fluids. Some varieties of foam dressings have a waterproof film covering the top surface and may or may not have an adhesive coating on the wound contact side or border. Foams are permeable to water and gas, and are able to absorb light to heavy exudate. This type of dressing is frequently used under compression stockings in patients with venous leg ulcers.
- Film dressings consist of a single, thin transparent sheet of polyurethane coated on one side with an adhesive. The sheet is permeable to gases and water vapor but impermeable to wound fluids. Film dressings retain moisture, are impermeable to bacteria and other contaminants, allow wound observation, and do not require a secondary dressing. Excessive fluid buildup may break the adhesive seal and allow leakage. Film dressings are intended for superficial wounds with little exudate and are commonly used as a secondary dressing to attach a primary absorbent dressing. The dressing may remain in place for up to seven days if excessive fluid does not accumulate. Film dressings have been used extensively to treat split-thickness graft donor sites.
- Alginate dressings are made from calcium or calcium-sodium salts of natural polysaccharides derived from brown seaweed. When the alginate material comes into contact with sodium-rich wound exudates, an ion exchange takes place and produces a hydrophilic gel. This hydrophilic gel is capable of absorbing up to 20 times its weight and does not adhere to the wound. This dressing can remain in place for about seven days if enough exudate is present to prevent drying. This category of dressing is best suited for moist, moderate-to-heavy exuding wounds. Alginate dressings require a secondary dressing, such as a film dressing, to hold them in place and to prevent the alginate from drying out.
- Hydrofiber dressing is composed of sodium carboxymethylcellulose fibers.103 The fibers maintain a moist wound environment by absorbing large amounts of exudate and forming a gel. This dressing is not intended for lightly exuding wounds. A secondary dressing is required.
- Hydrogel sheets are three-dimensional networks of cross-linked hydrophilic polymers. Their high water content provides moisture to the wound, but these dressings can absorb small-to-large amounts of fluid, depending on their composition. Depending on wound exudate levels, hydrogels may require more frequent dressing changes, every 1–3 days, compared with other synthetic dressings. Hydrogel sheets can be used on most wound types but may not be effective on heavily exuding wounds. The gel may also contain additional ingredients such as collagens, alginate, or complex carbohydrates. Amorphous hydrogels can donate moisture to a dry wound with eschar and facilitate autolytic débridement in necrotic wounds. A second dressing may be used to retain the gel in shallow wounds.

### Growth Factors

Growth factors have the potential to be important options when treating wounds. Becaplermin (Regranex gel, Ortho-McNeil Pharmaceutical, Inc., Titusville, NJ, USA) contains human recombinant PDGF and has been approved by FDA for treating diabetic neuropathic ulcers with adequate peripheral circulation.104 Four randomized controlled trials have demonstrated that becaplermin is more effective than placebo in promoting diabetic foot ulcer healing. In these studies becaplermin had a complete healing rate of 50 percent with a mean of 14 weeks to healing compared with 36 percent at 20 weeks for placebo. However, becaplermin's clinical experience outside these RCTs has not been as positive. In everyday clinical situations the healing rates have been reported to be closer to 33 percent for becaplermin and 26 percent for controls. The high cost of the drug coupled with the less-than-expected healing rates may explain why becaplermin has not been more widely used.

## U.S. Food and Drug Administration Regulations Governing Skin Substitute Products

The U.S. Food and Drug Administration (FDA) does not refer to any product or class of products as “skin substitutes.” However, products commonly described as “skin substitutes” are regulated by FDA under one of the four categories described below depending on the origin and composition of the product.

### Human Cells, Tissues, and Cellular and Tissue-Based Products

Cells and tissues taken from human donors and transplanted to a recipient are regulated under PHS 361 [21 CFR 1270 & 1271]. This regulation describes the rules concerning the use of HCT/Ps for human medical purposes. The final rule, 21 CFR Part 1271, became effective on April 4, 2001, for human tissues intended for transplantation that are regulated under section 361 of the PHS Act and 21 CFR Part 1270. HCT/Ps are regulated by the Center for Biologics Evaluation and Research (CBER). CBER is responsible for regulating biological and related products including blood, vaccines, allergenics, tissues, and cellular and gene therapies. Establishments producing HCT/Ps must register with FDA and list their HCT/Ps. HCT/Ps establishments are not required to demonstrate the safety or effectiveness of their products and FDA does not evaluate the safety or effectiveness of these products.

As defined in 21 CFR Part 1271, HCT/Ps “means articles containing or consisting of human cells or tissues that are intended for implantation, transplantation, infusion, or transfer into a human recipient. Examples of HCT/Ps include, but are not limited to, bone, ligament, skin, dura mater, heart valve, cornea, hematopoietic stem/progenitor cells derived from peripheral and cord blood, manipulated autologous chondrocytes, epithelial cells on a synthetic matrix, and semen or other reproductive tissue.” Cells, tissues, and organs derived from animals other than humans are not considered HCT/Ps. HCT/Ps are minimally manipulated and are intended for homologous use only, meaning they are used for “the repair, reconstruction, replacement, or supplementation of a recipient's cells or tissues with an HCT/Ps that performs the same basic function or functions in the recipient as in the donor.” According to the regulations an “HCT/P does not have a systemic effect and is not dependent upon the metabolic activity of living cells for its primary function; or the HCT/P has a systemic effect or is dependent upon the metabolic activity of living cells for its primary function, and is for autologous use; is for allogeneic use in a first-degree or second-degree blood relative; or is for reproductive use.”105

### Premarket Approval

Premarket approval (PMA) by FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices. FDA has three regulatory classes for medical devices, based on the degree of control necessary to assure that the devices are safe and effective. A Class III device “supports or sustains human life, are of substantial importance in preventing impairment of human health, or presents a potential, unreasonable risk of illness or injury. Insufficient information exists on a Class III device so that performance standards (Class II) or general controls (Class I) cannot provide reasonable assurance that the device is safe and effective for its intended use.” Before Class III devices can be marketed, they must have an approved PMA application. “Premarket approval by FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices.”7

According to FDA documents a “Premarket Approval (PMA) application is a scientific, regulatory documentation to FDA to demonstrate the safety and effectiveness of the class III device.” The application must contain “valid clinical information and scientific analysis on sound scientific reasoning” with “sufficient valid scientific evidence” to allow FDA to determine that the device is “safe and effective for its intended use(s).” PMAs are typically reviewed by an FDA advisory committee that provides FDA with recommendations on whether to approve the application.7 Therefore, wound care products regulated under the PMA process will require evidence that they promote wound healing before they are approved for marketing.

### 510(k) Submissions

According to FDA documents a “510(k) is a premarket submission made to FDA to demonstrate that the device to be marketed is at least as safe and effective, that is, substantially equivalent (SE), to a legally marketed device (21 CFR 807.92(a)(3)) that is not subject to PMA. Submitters must compare their device to one or more similar legally marketed devices and make and support their substantial equivalency claims. A legally marketed device, as described in 21 CFR 807.92(a)(3), is a device that was legally marketed prior to May 28, 1976 (preamendments device), for which a PMA is not required, or a device which has been reclassified from Class III to Class II or I, or a device which has been found SE through the 510(k) process. The legally marketed device(s) to which equivalence is drawn is commonly known as the ‘predicate.’ Although devices recently cleared under 510(k) are often selected as the predicate to which equivalence is claimed, any legally marketed device may be used as a predicate.”8

Unlike PMA, 510(k) confers reasonable assurance of safety and effectiveness via demonstration of substantial equivalence to a legally marketed device that does not require premarket approval. Substantial equivalence means that the new device is as safe and effective as the predicate device(s). Section 510(k) requires the manufacturer of a new device to submit a premarket notification report containing information that allows FDA to determine whether the new device is “substantially equivalent”' to a legally marketed device that does not require premarket approval. Unless exempted from premarket notification requirements, the new device may not be marketed, under section 510(k), unless it receives a substantial equivalence order from FDA or an order reclassifying the device into class I or an exempt class II device. According to FDA documents “Substantial equivalence is established with respect to intended use, design, energy used or delivered, materials, chemical composition, manufacturing process, performance, safety, effectiveness, labeling, biocompatibility, standards, and other characteristics, as applicable.” Submission of new clinical data showing equivalence is usually not part of the application.8 Therefore, wound care products regulated under the 510(k) process will not typically require clinical evidence to establish effectiveness in wound healing, as compared with products regulated under the PMA process in which substantial clinical evidence is always required.

### Humanitarian Device Exemption

According to FDA documents, “An Humanitarian Use Device (HUD) is a device that is intended to benefit patients by treating or diagnosing a disease or condition that affects or is manifested in fewer than 4,000 individuals in the United States per year. A device manufacturer's research and development costs could exceed its market returns for diseases or conditions affecting small patient populations. The HUD provision of the regulation provides an incentive for the development of devices for use in the treatment or diagnosis of diseases affecting these populations.

“To obtain approval for an HUD, a humanitarian device exemption (HDE) application is submitted to FDA. An HDE is similar in both form and content to a premarket approval (PMA) application, but is exempt from the effectiveness requirements of a PMA. An HDE application is not required to contain the results of scientifically valid clinical investigations demonstrating that the device is effective for its intended purpose. The application, however, must contain sufficient information for FDA to determine that the device does not pose an unreasonable or significant risk of illness or injury, and that the probable benefit to health outweighs the risk of injury or illness from its use, taking into account the probable risks and benefits of currently available devices or alternative forms of treatment. Additionally, the applicant must demonstrate that no comparable devices are available to treat or diagnose the disease or condition, and that they could not otherwise bring the device to market.” HDE approval is based on evidence of probable benefit in a disease population occurring at a frequency of less than 4,000 patients per year in the United States.6