# Evidence Tables

## Key Question 2

Table 27 Basic study design and conduct information for studies of Apligraf and Graftskin

Table 28 Basic study design and conduct information for studies of Dermagraft

Table 29 Basic study design and conduct information for studies of Graftjacket

Table 30 Basic study design and conduct information for studies of HYAFF and Talymed

Table 31 Basic study design and conduct information for studies of Oasis

Table 32 Assessment of wound closure in included trials

Table 33 Methods used for wound measurement at time of enrollment in trials

Table 34 Patient enrollment criteria for studies of Apligraf and Graftskin

Table 35 Patient enrollment criteria for studies of Dermagraft

Table 36 Patient enrollment criteria for studies of Graftjacket

Table 37 Patient enrollment criteria for studies of HYAFF and Talymed

Table 38 Patient enrollment criteria for studies of Oasis

Table 39 Description of treatments in studies of Apligraf and Graftskin

Table 40 Description of treatments in studies of Dermagraft

Table 41 Description of treatments in studies of Graftjacket

Table 42 Description of treatments in studies of HYAFF and Talymed

Table 43 Description of treatments in studies of Oasis

Table 44 Patient characteristics in studies of Apligraf and Graftskin

Table 45 Patient characteristics in studies of Dermagraft

Table 46 Patient characteristics in studies of Graftjacket

Table 47 Patient characteristics in studies of HYAFF and Talymed

Table 48 Patient characteristics in studies of Oasis

Table 49 Clinical results related to wound healing in studies of Apligraf and Graftskin

Table 50 Clinical results related to wound healing in studies of Dermagraft

Table 51 Clinical results related to wound healing in studies of Graftjacket

Table 52 Clinical results related to wound healing in studies of HYAFF and Talymed

Table 53 Clinical results related to wound healing in studies of Oasis

Table 54 Studies reporting wound recurrence after 12 weeks

## Key Question 3

Table 55 Reports of adverse events in studies of Apligraf and Graftskin

Table 56 Reports of adverse events in studies of Dermagraft

Table 57 Reports of adverse events in studies of Graftjacket

Table 58 Reports of adverse events in studies of HYAFF and Talymed

Table 59 Reports of adverse events in studies of Oasis