# Risk of Bias in the Evidence Base

## Key Question 2

Risk-of-Bias Questions:

Selection Bias
1. Did the study use appropriate randomization methods?
2. Was there concealment of treatment-group allocation?
3. Were the mean wound sizes at the start of treatment similar (no more than a 15 percent difference) between groups?
4. Were the mean wound durations at the start of treatment similar (no more than a 15 percent difference) between groups?
5. Were the numbers of comorbidities similar (no more than a 15 percent difference) at the start of treatment between groups?

Detection Bias
6 Was the wound assessor blinded to the patient's treatment group?

Performance Bias
7 Outside of the skin substitute and comparator, did patients receive identical treatment for their wounds?

Attrition Bias
8 Did 85 percent or more of enrolled patients provide data at the time point of interest?
9 Was there a 15 percent or less difference in completion rates in the study arms?

Table 22 Risk-of-bias assessments for Apligraf and Graftskin studies (rated as low, moderate, or high risk)

Study | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | Risk of Bias
DiDomenico et al. 2011^64^ | NR | NR | Y | NR | NR | N | Y | Y | Y | Moderate
Edmonds M. 2009^53^ | Y | Y | Y | Y | Y | NR | Y | Y | Y | Low
Veves et al. 2001^67^ | Y | Y | Y | Y | Y | NR | Y | Y | Y | Low
Falanga et al. 1998^63^ | Y | N | Y | NR | Y | NR | Y | Y | Y | Low

Based on complete wound healing as the primary outcome of interest.

DiDomenico et al. compared Apligraf with TheraSkin

N: No; NR: Not reported; Y: Yes

Table 23 Risk-of-bias assessments for Dermagraft studies (rated as low, moderate, or high risk)

Study | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | Risk of Bias
Krishnamoorthy et al. 2003^55^ | Y | Y | NR | NR | NR | N | Y | Y | N | Moderate
Marston et al. 2003^56^ | N | N | Y | N | NR | NR | Y | N | NR | Moderate
Naughton et al. 1997^62^ | NR | NR | NR | NR | NR | NR | NR | N | Y | Unclear
Gentzkow et al. 1996^65^ | N | Y | N | N | NR | NR | Y | Y | Y | Moderate

Based on complete wound healing as the primary outcome of interest

N: No; NR: Not reported; Y: Yes

Table 24 Risk-of-bias assessments for Graftjacket studies (rated as low, moderate, or high risk)

Study | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | Risk of Bias
Reyzelman et al. 2009^66^ | Y | Y | N | Y | Y | N | Y | Y | Y | Low
Brigido SA. 2006^59^ | NR | NR | NR | NR | NR | N | Y | Y | Y | Moderate

Based on complete wound healing as the primary outcome of interest

N: No; NR: Not reported; Y: Yes

Table 25 Risk-of-bias assessments for HYAFF and Talymed studies (rated as low, moderate, or high risk)

Study | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | Risk of Bias
Kelechi et al. 2011^61^ | Y | Y | Y | Y | N | N | Y | Y | Y | Low
Uccioli et al. 2011^68^ | Y | Y | N | Y | Y | N | Y | Y | Y | Low
Caravaggi et al. 2003^58^ | N | Y | Y | Y | Y | N | Y | N | Y | Low

Based on complete wound healing as the primary outcome of interest

Kelechi et al. 2011 compared Talymed (pGlcNAc) to nonadherent absorptive primary dressing

N: No; Y: Yes

Table 26 Risk-of-bias assessments for Oasis studies (rated as low, moderate, or high risk)

Study | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | Risk of bias
Romanelli et al. 2010^57^ | NR | NR | Y | Y | NR | N | Y | Y | Y | Moderate
Landsman et al. 2008^54^ | N | NR | Y | NR | NR | N | Y | Y | Y | Moderate
Romanelli et al. 2007^60^ | N | NR | Y | Y | NR | N | Y | Y | Y | Moderate
Mostow et al. 2005^69^ | Y | Y | Y | NR | NR | N | Y | Y | Y | Low
Niezgoda et al. 2005^70^ | Y | Y | Y | NR | N | n | Y | N | Y | Moderate

Based on complete wound healing as the primary outcome of interest

N: No; NR: Not reported; Y: Yes