# Methods of Identifying the Literature

## Electronic Database Searches

Table 17 Databases searched for relevant information

Name | Date Limits | Platform/Provider
CINAHL | 1996–May 29, 2012 | EBSCO
Clinicaltrials.gov | May 29, 2012 | www.clinicaltrials.gov
Cochrane Library | 1996–May 17, 2012 | Wiley
EMBASE (Excerpta Medica) | 1996–May 17, 2012 | OVID
Health Devices Alerts | 1996–August 16, 2011 | ECRI Institute
Health Technology Assessment Information Services (HTAIS) | 1996–August 15, 2011 | ECRI Institute
Healthcare Product Comparison System (HCPCS) | 1996–August 16, 2011 | ECRI Institute
Healthcare Standards Database | 1996–August 15, 2011 | ECRI Institute
MEDLINE | 1996–May 17, 2012 | OVID
National Institute for Health and Clinical Effectiveness | August 17, 2011 | National Health Service (UK)
PubMed (In process and Publisher subsets) | 1996–May 17, 2012 | National Library of Medicine
U.S. Food and Drug Administration | August 12, 2011 | www.fda.gov
U.S. National Guideline Clearinghouse™ (NGC) | August 15, 2011 | www.ngc.gov

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI Institute's collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

The search strategies employed combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategy below is presented in OVID syntax; the search was simultaneously conducted across EMBASE and MEDLINE. A parallel strategy was used to search CINAHL, PUBMED, and the databases comprising the Cochrane Library.

## Regulatory

In order to address Key Question 1, an extensive search of the U.S. Food and Drug Administration (FDA) Web site was conducted to determine regulatory classification and status of skin substitute products. The following FDA resources were searched:

- Device Classification database
- Premarket Approval (PMA) database
- 510(k) Marketing Clearance database
- List of Humanitarian Device Exemptions
- Code of Federal Regulations
- Center for Biologics Evaluation and Research

## Medical Subject Headings (MeSH), EMTREE and Keywords

Conventions:

OVID

$ | = | truncation character (wildcard)
Exp | = | “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary's hierarchy)
.de. or / | = | limit controlled vocabulary heading
.fs. | = | floating subheading
.hw. | = | limit to heading word
.md. | = | type of methodology (PsycINFO)
.mp. | = | combined search fields (default if no fields are specified)
.pt. | = | publication type
.ti. | = | limit to title
.tw. | = | limit to title and abstract fields

PubMed

[mh] | = | MeSH heading
[majr] | = | MeSH heading designated as major topic
[pt] | = | publication type
[sb] | = | subset of PubMed database (PreMEDLINE, Systematic, OldMEDLINE)
[sh] | = | MeSH subheading (qualifiers used in conjunction with MeSH headings)
[tiab] | = | keyword in title or abstract

Table 18 Topic-specific search terms

Concept | Controlled Vocabulary | Keywords
Skin substitutes | Skin, artificial/ Artificial skin/ Tissue scaffold/ Tissue scaffolds/ | Acellular dermal matrix$ hADM artificial dermis artificial skin autologous epidermal cell culture$ bilayer$ living cell$ bioengineered skin composite substitute dermal construct$ dermal equivalent$ dermal regeneration template$ dermal repair scaffold$ dermal substitute$ dermal template$ engineered skin epidermal equivalent$ extracellular matrix skin equivalent$ skin replacement$ skin substitute$ smart matrix
Skin substitute products | NA | Alloderm Apligraf Dermagraft Integra Oasis Primatrix TheraSkin Matristem Hyalomatrix Graftjacket Gammagraft Cymetra FlexHD AllopatchHD AlloMax AlloSkin Arthroflex DermACELL MemoDerm Matrix HD Strattice Biobrane Celaderm DressSkin Epicel Epidex EZ-Derm Graftskin Laserskin Lyofoam Lyomousse Matriderm Orcel Permacol Permaderm Puros dermis Suprathel Syspurderm Syspur-derm Tissuemend transcyte
Wounds | Exp wounds/ Exp injuries/ Exp wound healing/ Exp injury/ Diabetic foot/ Exp skin ulcer/ Exp skin ulcers Chronic wound/ | Wound$ Ulcer$ Sore$ Bedsore$ Decubitus Pressure sore$ Pressure ulcer$ Diabet$
Chronic | Chronic disease/ Chronic wound/ | Chronic Intractable Persistent Nonhealing Non healing

## EMBASE/Medline

Table 19 English language, human, randomized controlled trial/systematic review/meta-analysis/remove overlap

Set Number | Concept | Search Statement | # Downloaded
| Sets 1–3 represent the interventions of interest
1 | Skin substitutes | skin, artificial/ or artificial skin/ or tissue scaffold/ or tissue scaffolds/
2 | | (Accellular dermal matrix or hADM or artificial dermis or artificial skin or autologous epidermal cell culture$ or bilayer$ living cell$ or bioengineered skin or composite substitute or dermal construct$ or dermal equivalent$ or dermal regeneration template$ or dermal repair scaffold$ or dermal substitute$ or dermal template$ or engineered skin or epidermal equivalent$ or extracellular matrix or skin equivalent$ or skin replacement$ or skin substitute$ or smart matrix).mp.
3 | | (alloderm or apligraf or dermagraft or integra or oasis or primatrix or TheraSkin or matristem or hyalomatrix or graftjacket or gammagraft or cymetra or Flex HD or AlloPatch HD or AlloMax or AlloSkin or Arthroflex or DermACELL or MemoDerm or Matrix HD or Strattice OR biobrane OR celaderm OR dresskin OR epicel OR epidex OR EZ-derm OR graftskin OR laserskin OR lyofoam OR lyomousse OR matriderm OR orcel OR permacol OR permaderm OR puros dermis OR suprathel OR syspurderm OR syspur-derm OR tissuemend OR transcyte)
4 | | or/1-3
| Sets 5 through 6 represent the condition of interest
5 | Chronic wounds | ((exp wounds/ and injuries/) or exp wound healing/ or exp injury/) and (chronic disease/ or chronic.hw. or chronic.mp. or intractable.mp. or persistent.mp. or nonhealing.mp. or nonhealing.mp.)
6 | | Diabetic foot/ or exp skin ulcer/ or exp skin ulcers/ or chronic wound/ or decubitus.mp. or bedsore$.mp. or ((bed or diabet$ or pressure) adj2 (sore$ or ulcer$)).mp.
7 | | or/5-6
8 | Set 8 encompasses all three key questions | 4 and 7 | 115
| | Remove 18 references with a primary focus of burn patients and 2 duplicate references | 95

Table 20 Documents that were retrieved and then excluded

Reference | Comparisons | Reason for Exclusion
Chern et al. 2010^1^ | Acute surgical wounds and applicability to dermatologic surgery | Review
Steinberg et al. 2010^162^ | Apligraf vs. standard therapy | Not original research, reanalysis of published studies
Teng et al. 2010^163^ | Diabetic foot ulcers | Systematic Review
Gibbs et al. 2009^164^ | Tissue-engineered, full thickness autologous skin, Tiscover, consisting of a differentiated and pigmented epidermis on fibroblast populated human dermis, is cultured from 3 mm skin biopsies vs. standard treatment | Abstract only
Langer and Rogowski 2009^165^ | Chronic leg ulcers, diabetic foot ulcers | Systematic Review
Barber et al. 2008^166^ | Chronic leg ulcers, diabetic foot ulcers | Systematic Review
Blozik and Scherer 2008^167^ | Diabetic foot ulcers | Systematic Review
Cardinal et al. 2008^168^ | Dermagraft, retrospective reanalysis | Reanalysis of published studies
Chow et al. 2008^169^ | Diabetic foot ulcers | Health economic review
Jones and Nelson 2007^98^ | Venous leg ulcers | Systematic Review
Vowden et al. 2007^170^ | Amelogenin extracellular matrix protein plus compression vs. compression therapy alone | Not a skin substitute, not FDA approved
O'Donnell and Lau 2006^171^ | Chronic venous ulcer | Systematic Review
Brigido et al. 2004^172^ | Graftjacket vs. conventional treatment | No outcomes of interest were reported because study lasted only 4 weeks.
Ehrlich 2004^173^ | Understanding experimental biology of skin equivalent: from laboratory to clinical use in patients with burns and chronic wounds | Review
Payne et al. 2004^174^ | Dermagraft vs. conventional therapy | Outcomes were reported from less than 50% of the enrolled patients
Tausche et al. 2004^175^ | EpiDex trade mark, a tissue-engineered, fully differentiated autologous epidermal equivalent derived from keratinocytes vs. split-thickness skin autografting | Not a commercially available product
Hanft and Surprenant 2002^176^ | Dermagraft vs. saline-moistened gauze alone | Part of a larger study already included in the report
Falanga 2000^177^ | Graftskin (Apligraf) vs. compression therapy alone | Review
Harding et al. 2000^178^ | Chronic venous leg ulcers and pressure sores | Systematic Review
Falanga et al. 1999^161^ | Apligraf vs. compression therapy alone | Subgroup analysis of prior published study

Table 21 Articles excluded at the abstract level

Reference | Reason for Exclusion
Warriner and Cardinal 2011^179^ | Not an RCT
Landsman et al. 2011^180^ | Not an RCT
Romanelli et al. 2008^181^ | Not a skin substitute
Romanelli et al. 2008^182^ | Review
Hu et al. 2006^183^ | Acute wound
Vowden et al. 2006^184^ | Not a skin substitute
Chester et al. 2004^185^ | Review
Jeschke et al. 2004^186^ | Acute wound
Omar et al. 2004^187^ | Less than 10 patients per treatment arm
Saap et al. 2004^188^ | Not an RCT
Sams et al. 2002^189^ | Less than 10 patients per treatment arm
Bass and Phillips 2007^190^ | Review
Grey et al. 1998^191^ | Not an RCT
Fivenson and Scherschum 2003^192^ | Not an RCT
Kirsner et al. 2002^193^ | Not an RCT
Brem et al 2001^194^ | Not an RCT
Dougherty 2008^195^ | Not an RCT
Karr 2011^196^ | Not an RCT
Ortega-Zilic et al. 2010^197^ | Not an RCT
Mizune et al. 2010^198^ | Not an RCT
Kirsner et al. 2010^199^ | Not an RCT
Clerici et al. 2010^200^ | Not an RCT
Chen et al. 2010^201^ | Not an RCT
Brigido et al. 2009^202^ | Not an RCT
Han et al. 2009^203^ | Not an RCT
Renner et al. 2009^204^ | Not an RCT
Ramelet et al. 2009^205^ | Not an RCT
Canonico et al. 2009^206^ | Not an RCT
Vriens et al. 2008^207^ | Not an RCT
Winters et al. 2008^208^ | Not an RCT
Nie et al. 2007^209^ | Not an RCT
Mermet et al. 2007^210^ | Not an RCT
Yonexawa et al. 2007^211^ | Not an RCT
Gibes et al. 2006^212^ | Not an RCT
Martin et al. 2005^213^ | Not an RCT
Moustafa et al. 2004^214^ | Not an RCT
Redekop et al. 2003^215^ | Not an RCT
Phillips et al. 2002^216^ | Not an RCT
Browne et al. 2001^217^ | Not an RCT
Sibbald et al. 2001^218^ | Not an RCT
Yamaguchi et al. 2001^219^ | Not an RCT
Falabella et al. 2000^220^ | Not an RCT
Brem et al. 2000^221^ | Not an RCT
Monami et al. 2011^222^ | Not an RCT
Kerstein et al. 2002^223^ | Not an RCT
Sopata et al. 2002^224^ | Not a skin substitute
Chockalingam et al. 2001^225^ | Not a skin substitute
Micallef et al. 2010^226^ | Not an RCT
Tauzin et al. 2009^227^ | Not an RCT
Upton et al 2010^228^ | Not an RCT
Tang et al. 2010^229^ | Not an RCT
Faulhaber et al. 2010^230^ | Not an RCT
Hiles et al. 2009^231^ | Not a chronic wound
Huldt-Nystrom et al. 2008^232^ | Not an RCT
Russo et al. 2006^233^ | Not an RCT
Boyce 2004^234^ | Review
Eming et al. 2002^235^ | Review
Cavorsi 2000^236^ | Review
Moneta et al. 1999^237^ | Review
Shaikh et al. 2007^238^ | Acute wound

RCT: Randomized controlled trial