# Patient Evaluation

Evaluation of hypertensive patients has three objectives: (1) to assess lifestyle and identify other cardiovascular risk factors or concomitant disorders that may affect prognosis and guide treatment (table 6); (2) to reveal identifiable causes of high BP (table 7); and (3) to assess the presence or absence of target organ damage and CVD.

Table 6 Cardiovascular risk factors

Major Risk Factors
Hypertension^*^
Age (older than 55 years for men, 65 years for women)^†^
Diabetes mellitus^*^
Elevated LDL (or total) cholesterol, or low HDL cholesterol^*^
Estimated GFR <60 mL/min
Family history of premature CVD (men <55 years of age or women <65 years of age)
Microalbuminuria
Obesity^*^ (BMI ≥30 kg/m^2^)
Physical inactivity
Tobacco usage, particularly cigarettes
Target Organ Damage
Heart
LVH
Angina/prior MI
Prior coronary revascularization
Heart failure
Brain
Stroke or transient ischemic attack
Dementia
CKD
Peripheral arterial disease
Retinopathy

BMI, body mass index; CKD, chronic kidney disease; CVD, cardiovascular disease; GFR, glomerular filtration rate; HDL, high-density lipoprotein; LDL, low-density lipoprotein; LVH, left ventricular hypertrophy; MI, myocardial infarction

* Components of the metabolic syndrome. Reduced HDL and elevated triglycerides are components of the metabolic syndrome. Abdominal obesity also is a component of metabolic syndrome.

† Increased risk begins at approximately 55 and 65 years of age for men and women, respectively. Adult Treatment Panel III used earlier age cut points to suggest the need for earlier action.

Table 7 Identifiable causes of hypertension

Chronic kidney disease
Coarctation of the aorta
Cushing's syndrome and other glucocorticoid excess states including chronic steroid therapy
Drug induced or drug related (see table 18)
Obstructive uropathy
Pheochromocytoma
Primary aldosteronism and other mineralocorticoid excess states
Renovascular hypertension
Sleep apnea
Thyroid or parathyroid disease

Patient evaluation is made through medical history, physical examination, routine laboratory tests, and other diagnostic procedures. The physical examination should include: an appropriate measurement of BP, with verification in the contralateral arm; an examination of the optic fundi; a calculation of body mass index (BMI) (measurement of waist circumference is also very useful); an auscultation for carotid, abdominal, and femoral bruits; a palpation of the thyroid gland; a thorough examination of the heart and lungs; an examination of the abdomen for enlarged kidneys, masses, distended urinary bladder, and abnormal aortic pulsation; a palpation of the lower extremities for edema and pulses; and neurological assessment.

Data from epidemiological studies and clinical trials have demonstrated that elevations in resting heart rate and reduced heart-rate variability are associated with higher cardiovascular risk. In the Framingham Heart Study, an average resting heart rate of 83 beats per minute was associated with a substantially higher risk of death from a cardiovascular event than the risk associated with lower heart rate levels.^64^ Moreover, reduced heart-rate variability was also associated with an increase in cardiovascular mortality.^65^

No clinical trials have prospectively evaluated the impact of reduced heart rate on cardiovascular outcomes.

## Laboratory Tests and Other Diagnostic Procedures

Routine laboratory tests recommended before initiating therapy include a 12-lead electrocardiogram; urinalysis; blood glucose and hematocrit; serum potassium, creatinine (or the corresponding estimated glomerular filtration rate [eGFR]), and calcium;^66^ and a lipoprotein profile (after a 9- to 12-hour fast) that includes high-density lipoprotein cholesterol (HDL-C), low-density lipoprotein cholesterol (LDL-C), and triglycerides. Optional tests include measurement of urinary albumin excretion or albumin/creatinine ratio (ACR) except for those with diabetes or kidney disease where annual measurements should be made. More extensive testing for identifiable causes is not generally indicated unless BP control is not achieved or the clinical and routine laboratory evaluation strongly suggests an identifiable secondary cause (i.e., vascular bruits, symptoms of catecholamine excess, or unprovoked hypokalemia). (See Identifiable Causes of Hypertension for a more thorough discussion.) The presence of decreased GFR or albuminuria has prognostic implications as well. Studies reveal a strong relationship between decreases in GFR and increases in cardiovascular morbidity and mortality.^67,68^ Even small decreases in GFR increase cardiovascular risk.^67^ Serum creatinine may overestimate glomerular filtration. The optimal tests to determine GFR are debated, but calculating GFR from the recent modifications of the Cockcroft and Gault equations is useful.^69^

The presence of albuminuria, including microalbuminuria, even in the setting of normal GFR, is also associated with an increase in cardiovascular risk.^70–72^ Urinary albumin excretion should be quantitated and monitored on an annual basis in high-risk groups, such as those with diabetes or renal disease.

Additionally, three emerging risk factors (1) high-sensitivity C-reactive protein (HS-CRP); a marker of inflammation; (2) homocysteine; and (3) elevated heart rate may be considered in some individuals, particularly those with CVD but without other risk-factor abnormalities. Results of an analysis of the Framingham Heart Study cohort demonstrated that those with a LDL value within the range associated with low cardiovascular risk, who also had an elevated HS-CRP value, had a higher cardiovascular event rate as compared to those with low CRP and high LDL cholesterol.^73^ Other studies also have shown that elevated CRP is associated with a higher cardiovascular event rate, especially in women.^74^ Elevations in homocysteine have also been linked higher cardiovascular risk; however, the results with this marker are not as robust as those with high HS-CRP.^75,76^