# Introduction

For more than three decades, the National Heart, Lung, and Blood Institute (NHLBI) has administered the National High Blood Pressure Education Program (NHBPEP) Coordinating Committee, a coalition of 39 major professional, public, and voluntary organizations and 7 Federal agencies. One important function is to issue guidelines and advisories designed to increase awareness, prevention, treatment, and control of hypertension (high blood pressure [BP]).

Data from the National Health and Nutrition Examination Survey (NHANES) have indicated that 50 million or more Americans have high BP warranting some form of treatment.^1,2^ Worldwide prevalence estimates for hypertension may be as much as 1 billion individuals, and approximately 7.1 million deaths per year may be attributable to hypertension.^3^ The World Health Organization reports that suboptimal BP (>115 mmHg SBP) is responsible for 62 percent of cerebrovascular disease and 49 percent of ischemic heart disease (IHD), with little variation by sex. In addition, suboptimal BP is the number one attributable risk factor for death throughout the world.^3^

Considerable success has been achieved in the past in meeting the goals of the program. The awareness of hypertension among Americans has improved from a level of 51 percent in the period 1976–1980 to 70 percent in 1999–2000 (table 1). The percentage of patients with hypertension receiving treatment has increased from 31 percent to 59 percent in the same period, and the percentage of persons with high BP controlled to below 140/90 mmHg has increased from 10 percent to 34 percent. Between 1960 and 1991, median SBP for individuals ages 60–74 declined by approximately 16 mmHg (figure 1). These changes have been associated with highly favorable trends in the morbidity and mortality attributed to hypertension. Since 1972, age-adjusted death rates from stroke and coronary heart disease (CHD) have declined by approximately 60 percent and 50 percent, respectively (figures 2 and 3). These benefits have occurred independent of gender, age, race, or socioeconomic status. Within the last two decades, better treatment of hypertension has been associated with a considerable reduction in the hospital case-fatality rate for heart failure (HF) (figure 4). This information suggests that there have been substantial improvements.

Figure 1

Smoothed weighted frequency distribution, median, and 90th percentile of systolic blood pressure for ages 60–74 years: United States, 1960–1991

NHANES, National Health and Nutrition Examination Survey; NHES, National Health Examination Survey

Source: Burt VL, et al. Trends in the prevalance, awareness, treatment, and control of hypertension in the adult US population. Data from the health examination surveys, 1960 to 1991. Erratum in: Hypertension 1996;7(5):1192.

Figure 2

Percent decline in age-adjusted mortality rates for stroke by gender and race: United States, 1970–2000

Source: Prepared by Thom T, National Heart, Lung, and Blood Institute from Vital Statistics of the United States, National Center for Health Statistics. Death rates are age-adjusted to the 2000 U.S. census population.

Figure 3

Percent decline in age-adjusted mortality rates for coronary heart disease by gender and race: United States, 1970–2000

Source: Prepared by Thom T, National Heart, Lung, and Blood Institute from Vital Statistics of the United States, National Center for Health Statistics. Death rates are age-adjusted to the 2000 U.S. census population.

Figure 4

Hospital case-fatality rates for congestive heart failure for ages younger than 65 years and 65 years and older: United States, 1981–2000

Source: National Heart, Lung, and Blood Institute. Morbidity and Mortality: 2002 Chart Book on Cardiovascular, Lung, and Blood Diseases. Chart 3–36. Accessed November 2003. http://www.nhlbi.nih.gov/resources/docs/cht-book.htm.

Table 1 Trends in awareness, treatment, and control of high blood pressure, 1976–2000^*^

| National Health and Nutrition Examination Survey, Percent
| 1976–80^1^ | 1988–91^1^ | 1991–94^2^ | 1999–2000^3^
Awareness | 51 | 73 | 68 | 70
Treatment | 31 | 55 | 54 | 59
Control ^†^ | 10 | 29 | 27 | 34

* Percentage of adults ages 18 to 74 years with SBP of 140 mmHg or greater, DBP of 90 mmHg or greater, or taking antihypertensive medication.

† SBP below 140 mmHg and DBP below 90 mmHg, and on antihypertensive medication.

Sources: ^1^ Data from Burt VL, et al. Prevalance of hypertension in the US adult population. Results from the Third National Health and Nutrition Examination Survey, 1988–1991. Hypertension 1995;26:60–9.

2 Data from The Sixth Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Arch Intern Med 1997;157:2413–46.

3 The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. JAMA 2003;289:2560–71.

However, these improvements have not been extended to the total population. Current control rates for hypertension in the United States are clearly unacceptable. Approximately 30 percent of adults are still unaware of their hypertension, >40 percent of individuals with hypertension are not on treatment, and two-thirds of hypertensive patients are not being controlled to BP levels <140/90 mmHg (table 1). Furthermore, the decline rates in CHD- and stroke-associated deaths have slowed in the past decade. In addition, the prevalence and hospitalization rates of HF, wherein the majority of patients have hypertension prior to developing HF, have continued to increase (figures 5 and 6). Moreover, there is an increasing trend in end-stage renal disease (ESRD) by primary diagnosis. Hypertension is second only to diabetes as the most common antecedent for this condition (figure 7). Undiagnosed, untreated, and uncontrolled hypertension clearly places a substantial strain on the health care delivery system.

Figure 5

Prevalence^*^ of congestive heart failure by race and gender, ages 25–74 years: United States, 1971–74 to 1999–2000

Note: White and Black in 1999–2000 exclude Hispanics.

Source: National Heart, Lung, and Blood Institute. Morbidity and Mortality: 2002 Chart Book on Cardiovascular, Lung, and Blood Diseases. Accessed November 2003. http://www.nhlbi.nih.gov/resources/docs/cht-book.htm and 1999–2000 unpublished data computed by Wolz M and Thom T, National Heart, Lung, and Blood Institute. June 2003.

Figure 6

Hospitalization rates for congestive heart failure, ages 45–64 years and 65 years and older: United States, 1971–2000

Source: National Heart, Lung, and Blood Institute. Morbidity and Mortality: 2002 Chart Book on Cardiovascular, Lung, and Blood Diseases. Chart 3–35. Accessed November 2003. http://www.nhlbi.nih.gov/resources/docs/cht-book.htm.

Figure 7

Trends in incident rates of end-stage renal disease, by primary diagnosis (adjusted for age, gender, race)

Source: United States Renal Data System. 2002. Figure 1.14. Accessed November 2003. http://www.usrds.org/slides.htm.