# Improving Hypertension Control

## Issues Dealing With Adherence to Regimens

Behavioral models suggest that the most effective therapy prescribed by the most careful clinician will control hypertension only if the patient is motivated to take the medication as directed and to establish and maintain a health-promoting lifestyle. Motivation improves when patients have positive experiences with, and trust in, their clinicians. Better communication improves outcomes; empathy builds trust and is a potent motivator (table 25).^374^

Table 25 Provide empathetic reinforcement

- Adopt an attitude of concern coupled with hope and interest in the patient's future.; - Provide positive feedback for blood pressure and behavioral improvement.; - If blood pressure is not at goal, ask about behaviors to achieve blood pressure control.; - Hold exit interviews to clarify regimen. A patient may tell you that they understand but tell the exit interviewer that they do not.; - Schedule more frequent appointments and health care personnel contact with patients who are not achieving goal blood pressure.

## What Can the Clinician Do?

Clinician-patient partnerships that are based on trust, respect, and a holistic knowledge of the patient correlate with positive outcomes of care, such as adherence, satisfaction, and improved health status. Patients often evaluate a clinician's competence by their customer service skills, not their clinical skills.^375^ Customer service includes ease of access, minimal waiting time, and a positive regard from the office staff; all are known to influence provider satisfaction and patient adherence. Clinicians are the role model and should train staff by providing a positive, interactive, empathetic environment. This will increase patients' comfort and willingness to participate in their own care.

## Clinical Inertia

There is a broad range of clinician commitment to optimal hypertension therapy (table 26). Failure to titrate or combine medications and to reinforce lifestyle modifications, despite knowing that the patient is not at goal BP, represents clinical inertia which must be overcome. This may be due in part to clinician focus on relieving symptoms, a lack of familiarity with clinical guidelines, or discomfort in titrating to a goal.^376^

Table 26 Clinician awareness and monitoring

- Anticipate adherence problems for young men.; - Consider nonadherence as a cause of:; - Failure to reach goal blood pressure; - Resistant hypertension; - Sudden loss of control.; - Encourage patients to bring in all medications from all physicians and other sources, whether prescription, complementary, or over-the-counter, to each visit for review and to rule out iatrogenic causes of elevated blood pressure.; - Ask what the patient takes for pain.; - Recognize depression and other psychiatric illnesses, including panic attacks, and manage appropriately.; - Be willing to change unsuccessful regimens and search for those more likely to succeed.

A number of approaches are available to overcome clinical inertia. One of the most effective is to use decision support systems that prompt the-clinician to advance therapy when a goal has not been achieved (table 27). Such systems can be electronic (computer- or personal digital assistant-based) or paper-based (flow charts, algorithms, guidelines). Feedback reminders from any source (computer-based, automated telephone-based, nurse care managers, outside auditors) can be very effective in not only helping to achieve BP goals but to alert clinicians to missed patient appointments, necessary prescription refills, and laboratory abnormalities.^377^

Table 27 Organize care delivery systems

- Schedule next appointment before patient leaves office.; - Use appointment reminders, preferably computer-based, and contact patients to confirm appointments.; - Follow up with patients who missed appointments.; - Use an office-based system approach for monitoring and followup (e.g., educate staff to provide patient encouragement, computer or chart reminders, disease management aids).

Patient-centered behavioral interventions, such as counseling, improve BP control (table 28).^378^ Nurse clinicians and pharmacists have proven their effectiveness in helping to achieve goal BP.^379^ Commercial health plans may provide resources for chart auditing or other assistance to improve BP control.^380^ Clinicians should periodically audit their own patient files to assess their degree of compliance and success with established goals and treatment interventions.

Table 28 Patient education about treatment

- Assess the patient's understanding and acceptance of the diagnosis of hypertension.; - Discuss patient's concerns, and clarify misunderstandings.; - Tell the patient the blood pressure reading, and provide a written copy.; - Come to agreement with the patient on goal blood pressure.; - Ask the patient to rate from 1 to 10 his or her chance of staying on treatment.; - Inform the patient about recommended treatment, and provide specific written information about the role of lifestyle including diet, physical activity, dietary supplements, and alcohol intake; use standard brochures when available.; - Elicit concerns and questions, and provide opportunities for the patient to state specific behaviors to carry out treatment recommendations.; - Emphasize:; - Need to continue treatment; - Control does not mean cure; - One cannot tell if blood pressure is elevated by "feeling or symptoms"; blood pressure must be measured.

The National Committee for Quality Assurance (NCQA) has established the Health Plan Employer Data and Information Set (HEDIS), a set of standardized performance measures designed to ensure that purchasers and consumers have the information they need to reliably assess quality of health care (http://www.ncqa.org/Programs/HEDIS). Enforcement of HEDIS guidelines by managed care organizations has successfully increased the appropriate use of ACEIs in HF and of BBs in patients who have suffered an MI. NCQA now monitors physician records for the percent of patients whose BP is <140/90 mmHg.^381^ BP control rates by monitored physicians have increased to as high as 59 percent. Patients should be told their BP on each visit and encouraged not only to ask for those numbers but to also inquire as to why BP is above the goal, if that is the case. They also should be given a written record to keep as their part of this commitment.

## Role of Other Health Care Professionals

Clinicians must work with other health care professionals (e.g., nurse case managers and other nurses, physician assistants, pharmacists, dentists, registered dietitians, licensed nutritionists, nutrition educators, optometrists, and podiatrists) to influence or reinforce instructions to improve patient lifestyles and BP control (table 29). Nurse-managed hypertension clinics, worksite occupational health departments, managed care organizations, pharmacists, and lay community workers have all contributed to better hypertension control. Public health nurses and community outreach workers in high-risk communities are also helpful through their efforts to screen, identify cases, refer and track followup appointments, and educate patients. All health care professionals must be committed to enhancing BP control through reinforcing messages about the risks of hypertension, the importance of managing both SBP and DBP and achieving goal BP, education about effective lifestyle interventions, pharmacologic therapies, and adherence to treatment.

Table 29 Collaborate with other health professionals

- Use complementary skills and knowledge of nurses, physician assistants, pharmacists, registered dietitians, optometrists, dentists, and podiatrists.; - Refer selected patients for more intensive counseling.

## Patient Factors

Patient attitudes are greatly influenced by cultural differences, beliefs, and previous experiences with the health system.^382^ These attitudes must be understood and respected if the clinician is to build trust and increase communication with patients and families (table 30). Clinicians should explain to patients that the terms "hypertension" and "high BP" are used interchangeably and that neither indicates an anxiety state. In addition to motivation, patients need specific education designed to help them modify their lifestyle and to take medications as prescribed to feel better and to reduce risks.

Table 30 Individualize the regimen

- Include patient in decision making.; - Simplify the regimen to once-daily dosing, if possible.; - Incorporate treatment into patient's daily lifestyle; e.g., take medications just before or after brushing teeth.; - Agree with the patient on realistic short-term objectives for specific components of the medication and lifestyle modification plan.; - Encourage discussion of diet and physical activity.; - Encourage discussion of adverse drug effects and concerns.; - Encourage self-monitoring with validated blood pressure devices.; - Minimize the cost of therapy; recognize financial issues and enlist local community and national programs to assist in affording medications.; - Indicate that adherence to the regimen will be a subject of discussion at each visit.; - Encourage gradual sustained weight loss.

### Characterization of Patients Leading to Tailored Therapy

There is a broad range of patient involvement in, and commitment to, hypertension therapy. Management strategies need to be focused on the patient's goals when providing advice and encouraging adherence. Optimal management strategies are likely to differ for patient types. Healthy lifestyles influence adherence to medication as well as a patient's beliefs and involvement with behaviors including food, beverages, physical activity, healthy weight, salt and alcohol consumption, and smoking. A cluster analysis of 727 hypertensive patients found that the individuals fell into 4 categories.^383^ The largest group (39 percent) was health-oriented, informed about hypertension, and took their medication. The second group (16 percent) tended to rely on medication rather than lifestyle to control their BP. The third group (22 percent) had the highest BMI, did not practice health-promoting lifestyles (except for low rates of alcohol consumption and tobacco abuse), often forgot to take their medication, and had a lower BP control rate. These patients may benefit most from clinical counseling and help with achieving lifestyle modifications; they will likely require more frequent office visits or contact with nurses or other providers. The patients in the last group (23 percent) were more likely to be male and young, knew less about hypertension, were least afraid of the consequences of hypertension or failure to take their medication, and were most likely to consume alcohol, abuse tobacco, and stop medication without informing their physician. This last group will probably require persistent reinforcement, information on the hazards related to lack of BP control, and small incremental goal setting by allied health care personnel. Involvement of family members or other social supports also may be useful (table 31).

Table 31 Promote social support systems

- With full permission of the patient, involve caring family members or other social support (e.g., faith-based or community organizations) in the treatment process.; - Suggest common interest group activities (e.g., a walking group) to enhance mutual support and motivation.

### Goal Setting and Behavioral Change

The clinician and patient must agree upon BP goals and an estimated achievement time, and those goals should be clearly recorded in the chart. With the support of the clinician, the patient must be empowered with the understanding that making behavioral changes is ultimately his or her responsibility. As people make behavioral changes, they progress through a series of stages (precontemplation, contemplation, preparation, action, and maintenance). Behavioral changes are more successfully facilitated using this approach, along with motivational interviewing, rather than assigning the same intervention to every patient.^384,385^

Patients can be asked to use a 1–10 ranking to indicate how likely they are to follow the plan. If not likely, the clinician can use motivational interviewing to identify the barriers to adherence. At visits where BP is above goal, alterations in the treatment plan should be made and documented accordingly. Home BP devices can be very useful in involving many patients in their own care. Clinicians must calibrate these devices (see Self-Measurement). This should be done, in part, by having the patient determine their BP with the device in the presence of the clinician. Home-determined BP tends to be approximately 5 mmHg lower than office BP, and this information should be considered when assessing progress toward the goal. However, office BP should still be used to determine whether a patient is at goal.

Patient satisfaction with health care providers predicts compliance with treatment. All clinicians need to provide positive, patient-centered care to satisfy and enable their patients to follow treatment. Some patient-centered behavioral interventions, like counseling, have been shown to improve BP control, while the evidence for structured training or self-monitoring is less clear.

## Economic Barriers

The cost of medications may be a barrier to effective treatment. Patients often perceive that lifestyle modifications such as following the DASH eating plan are expensive, but following these plans can be accomplished even on modest budgets. Nutrition educators offer classes in schools, communities, and worksites on food budgeting and meal planning. Clinicians should refer their patients to these classes. Medical nutrition therapy by registered dietitians improves the health of patients who have high cholesterol, diabetes, obesity, or other chronic disease risk factors.^386^ Patients should be advised that most lifestyle modifications may be cost-free or may even save money (e.g., smoking cessation and reduction of alcohol consumption). Further, the beneficial effects of lifestyle modification may include reduction in the amount and cost of prescribed medications and the cost of insurance. A patient adhering to the DASH eating plan may require less medication and save money. Patients need to understand the important difference between the price of a medication and the cost of nonadherence. The price of medication is the amount of money needed for purchase, and the cost is the outcome or consequences of not adhering to this treatment advice, which may include impaired quality of life, CVD, kidney failure, stroke, and even premature death. The identification of persons who can assist the patient with insurance concerns and social services may be important to overall adherence. Most pharmaceutical companies have special needs programs that are often handled through their marketing departments.

## Additional Sources of Information

Additional information is available at the NHLBI Web site http://www.nhlbi.nih.gov/.