# Genetics of Hypertension

The investigation of rare genetic disorders affecting BP has led to the identification of genetic abnormalities associated with several rare forms of hypertension, including mineralocorticoid-remediable aldosteronism, 11beta-hydroxylase and 17alpha-hydroxylase deficiencies, Liddle's syndrome, the syndrome of apparent mineralocorticoid excess, and pseudohypoaldosteronism type II.^82^ The individual and joint contributions of these genetic mutations to BP levels in the general population, however, are very small. Genetic association studies have identified polymorphisms in several candidate genes (e.g., angiotensinogen, alpha-adducin, beta- and DA-adrenergic receptors, and beta-3 subunit of G proteins), and genetic linkage studies have focused attention on several genomic sites that may harbor other genes contributing to primary hypertension.^83–85^ However, none of these various genetic abnormalities has been shown, either alone or in joint combination, to be responsible for any applicable portion of hypertension in the general population.