# Foreword

The complete version of the Seventh Report of the Joint National Committee on Prevention,Detection, Evaluation,and Treatment of High Blood Pressure (JNC7) provides additional scientific evidence to bolster other JNC 7 products:the JNC 7 Express; Facts About the DASH Eating Plan; Your Guide to Lowering High Blood Pressure; Reference Card from the JNC 7 for clinicians; Blood Pressure Wallet Card for patients;and Palm application of the JNC 7 recommendations.These educational materials are available on the NHLBI Web site http://www.nhlbi.nih.gov/.

The purpose of JNC reports is to synthesize the available scientific evidence and offer guidance to busy primary care clinicians. Readers of this report should remember that this document is intended as a guide, not a mandate. The National High Blood Pressure Education Program (NHBPEP) recognizes the responsible clinician's judgment regarding the management of patients remains paramount. Therefore, JNC documents are tools to be adopted and implemented in local and individual settings.

In the production of this report, much discussion was generated regarding the interpretation of the available scientific literature. However, after all of the discussions within the JNC 7 Executive Committee and the NHBPEP Coordinating Committee, as well as the many discussions at conferences and scientific meetings conducted in the United States and worldwide, the conclusion is that best management practice occurs when hypertension is treated to goal levels and blood pressure control is sustained over time. This is irrefutable but, unfortunately, hypertension treatment and control rates worldwide are simply not as good as they could be.

By developing this stellar landmark report, Dr. Aram Chobanian, the JNC 7 Executive Committee, and members of the NHBPEP Coordinating Committee, as well as the writers and the contributors to this document, have addressed the important public health issue of improving inadequate blood pressure control. Applying JNC 7 recommendations to clinical practice will prevent the devastating consequences of uncontrolled hypertension. I recommend this guideline to clinicians and public health workers with the conviction that its contents will indeed contribute to the further prevention of premature morbidity and mortality. Dr. Chobanian has our deep gratitude for leading the effort to develop this report in such a timely manner. His brilliant leadership is what made the JNC 7 and related materials possible. The NHBPEP will release other advisories as the scientific evidence becomes available.

Barbara M. Alving, M.D.

Acting Director

National Heart, Lung, and Blood Institute, and Chair, National High Blood Pressure Education Program Coordinating Committee