# Acknowlegements

## Chair

Aram V. Chobanian, M.D. (Boston University School of Medicine, Boston, MA)

## Executive Committee

George L. Bakris, M.D. (Rush University Medical Center, Chicago, IL); Henry R. Black, M.D. (Rush University Medical Center, Chicago, IL); William C. Cushman, M.D. (Veterans Affairs Medical Center, Memphis, TN); Lee A. Green, M.D., M.P.H. (University of Michigan, Ann Arbor, MI); Joseph L. Izzo, Jr., M.D. (State University of New York at Buffalo School of Medicine, Buffalo, NY); Daniel W. Jones, M.D. (University of Mississippi Medical Center, Jackson, MS); Barry J. Materson, M.D., M.B.A. (University of Miami, Miami, FL); Suzanne Oparil, M.D. (University of Alabama at Birmingham, Birmingham, AL); Jackson T. Wright, Jr., M.D., Ph.D. (Case Western Reserve University, Cleveland, OH)

## Executive Secretary

Edward J. Roccella, Ph.D., M.P.H. (National Heart, Lung, and Blood Institute, Bethesda, MD)

## Financial Disclosures

Dr. Chobanian has received honoraria for serving as a speaker from Monarch, Wyeth, Astra-Zeneca, Solvay, and Bristol-Myers Squibb.

Dr. Bakris has received honoraria for serving as a speaker from Astra-Zeneca, Abbott, Alteon, Biovail, Boerhinger-Ingelheim, Bristol-Myers Squibb, Forest, GlaxoSmithKline, Merck, Novartis, Sanofi, Sankyo, and Solvay; he has received funding/grant support for research projects from National Institutes of Health, Astra-Zeneca, Abbott, Alteon, Boerhinger-Ingelheim, Forest, GlaxoSmithKline, Merck, Novartis, Sankyo, and Solvay; he has served as a consultant/advisor for Astra-Zeneca, Abbott, Alteon, Biovail, Boerhinger-Ingelheim, Bristol-Myers Squibb, Forest, GlaxoSmithKline, Merck, Novartis, Sanofi, Sankyo, and Solvay.

Dr. Black has received honoraria for serving as a speaker from Astra-Zeneca, Bristol-Myers Squibb, Novartis, Pfizer, Pharmacia, and Wyeth-Ayerst; he has received funding/grant support for research projects from Bristol-Myers Squibb, Boehringer-Ingelheim, Merck, Pfizer, and Pharmacia; he has served as a consultant/advisor for Abbott, Astra-Zeneca, Biovail, Bristol-Myers Squibb, GlaxoSmithKline, Merck, Pfizer, and Pharmacia.

Dr. Carter has served as a consultant/advisor for Bristol-Myers Squibb.

Dr. Cushman has received funding/grant support for research projects from Astra-Zeneca, Merck, Pfizer, Kos, Aventis Pharma, King Pharmaceuticals, GlaxoSmithKline, and Boehringer-Ingelheim; he has served as a consultant/advisor for Bristol-Myers Squibb, Sanofi, GlaxoSmithKline, Novartis, Pfizer, Solvay, Pharmacia, Takeda, Sankyo, Forest, and Biovail.

Dr. Izzo has received honoraria for serving as a speaker from Boehringer-Ingelheim, Merck, Pfizer, Astra-Zeneca, Solvay, Novartis, Forest, and Sankyo; he has received funding/grant support for research projects from Boehringer-Ingelheim, Merck, Astra-Zeneca, Novartis, GlaxoSmithKline, and Biovail; he served as a consultant/advisor for Merck, Astra-Zeneca, Novartis, Intercure, Sankyo, and Nexcura; he has stock holdings in Intercure, Nexcura.

Dr. Jones has served as a consultant/advisor for Pfizer, Bristol-Myers Squibb, Merck, Forest, and Novartis.

Dr. Manger has served as a consultant/advisor for the NHBPEP Coordinating Committee.

Dr. Materson has served as a consultant/advisor for Unimed, Merck, GlaxoSmithKline, Novartis, Reliant, Tanabe, Bristol-Myers Squibb, Pfizer, Pharmacia, Noven, Boehringer-Ingelheim, and Solvay.

Dr. Oparil has received funding/grant support for research projects from Abbott Laboratories, Astra-Zeneca, Aventis, Boehringer-Ingelheim, Bristol-Myers Squibb, Eli Lilly, Forest, GlaxoSmithKline, Monarch, Novartis [Ciba], Merck, Pfizer, Sanofi/BioClin, Schering Plough, Schwarz Pharma, Scios Inc, GD Searle, Wyeth-Ayerst, Sankyo, Solvay, and Texas Biotechnology Corporation; she has served as a consultant/advisor for Bristol-Myers Squibb, Merck, Pfizer, Sanofi, Novartis, The Salt Institute, and Wyeth-Ayerst; she is also on the Board of Directors for the Texas Biotechnology Corporation.

Dr. Sowers has received honoraria for serving as a speaker from Med Com Vascular Biology Working Group and Joslin Clinic Foundation; he has received funding/grant support for research projects from Novartis and Astra-Zeneca.

Dr. Wright has received honoraria for serving as a speaker from Astra, Aventis, Bayer, Bristol-Myers Squibb, Forest, Merck, Norvartis, Pfizer, Phoenix Pharmaceuticals, GlaxoSmithKline, and Solvay/Unimed; he has received funding/grant support for research projects from Astra, Aventis, Bayer, Biovail, Bristol-Myers Squibb, Forest, Merck, Norvartis, Pfizer, Phoenix Pharmaceuticals, GlaxoSmithKline, and Solvay/Unimed.

## National High Blood Pressure Education Program Coordinating Committee

Claude Lenfant, M.D. (National Heart, Lung, and Blood Institute, Bethesda, MD); George L. Bakris, M.D. (Rush University Medical Center, Chicago, IL); Henry R. Black, M.D. (Rush University Medical Center, Chicago, IL); Vicki Burt, Sc.M., R.N. (National Center for Health Statistics, Hyattsville, MD); Barry L. Carter, Pharm.D., F.C.C.P. (University of Iowa, Iowa City, IA); Francis D. Chesley, Jr., M.D. (Agency for Healthcare Research and Quality, Rockville, MD); Jerome D. Cohen, M.D. (Saint Louis University School of Medicine, St. Louis, MO); Pamela J. Colman, D.P.M. (American Podiatric Medical Association, Bethesda, MD); William C. Cushman, M.D. (Veterans Affairs Medical Center, Memphis, TN); Mark J. Cziraky, Pharm.D., F.A.H.A. (Health Core, Inc., Newark, DE); John J. Davis, P.A.-C. (American Academy of Physician Assistants, Memphis, TN); Keith Copelin Ferdinand, M.D., F.A.C.C. (Heartbeats Life Center, New Orleans, LA); Ray W. Gifford, Jr., M.D., M.S. (Cleveland Clinic Foundation, Fountain Hills, AZ); Michael Glick, D.M.D. (New Jersey Dental School, Newark, NJ); Lee A. Green, M.D., M.P.H. (University of Michigan, Ann Arbor, MI); Stephen Havas, M.D., M.P.H., M.S. (University of Maryland School of Medicine, Baltimore, MD); Thomas H. Hostetter, M.D. (National Institutes of Diabetes and Digestive and Kidney Diseases, Bethesda, MD); Joseph L. Izzo, Jr., M.D. (State University of New York at Buffalo School of Medicine, Buffalo, NY); Daniel W. Jones, M.D. (University of Mississippi Medical Center, Jackson, MS); Lynn Kirby, R.N., N.P., C.O.H.N. (Sanofi-Synthelabo Research, Malvern, PA); Kathryn M. Kolasa, Ph.D., R.D., L.D.N. (Brody School of Medicine at East Carolina University, Greenville, NC); Stuart Linas, M.D. (University of Colorado Health Sciences Center, Denver, CO); William M. Manger, M.D., Ph.D. (New York University Medical Center, New York, NY); Edwin C. Marshall, O.D., M.S., M.P.H. (Indiana University School of Optometry, Bloomington, IN); Barry J. Materson, M.D., M.B.A. (University of Miami, Miami, FL); Jay Merchant, M.H.A. (Centers for Medicare & Medicaid Services, Washington, DC); Nancy Houston Miller, R.N., B.S.N. (Stanford University School of Medicine, Palo Alto, CA); Marvin Moser, M.D. (Yale University School of Medicine, Scarsdale, NY); William A. Nickey, D.O. (Philadelphia College of Osteopathic Medicine, Philadelphia, PA); Suzanne Oparil, M.D. (University of Alabama at Birmingham, Birmingham, AL); Otelio S. Randall, M.D., F.A.C.C. (Howard University Hospital, Washington, DC); James W. Reed, M.D., F.A.C.P., F.A.C.E. (Morehouse School of Medicine, Atlanta, GA); Edward J. Roccella, Ph.D., M.P.H. (National Heart, Lung, and Blood Institute, Bethesda, MD); Lee Shaughnessy (National Stroke Association, Englewood, CO); Sheldon G. Sheps, M.D. (Mayo Clinic, Rochester, MN); David B. Snyder, R.Ph., D.D.S. (Health Resources and Services Administration, Rockville, MD); James R. Sowers, M.D., F.A.C.P., F.A.C.E. (SUNY Health Science Center at Brooklyn, Brooklyn, NY); Leonard M. Steiner, M.S., O.D. (Eye Group, Oakhurst, NJ); Ronald Stout, M.D., M.P.H. (Procter and Gamble, Mason, OH); Rita D. Strickland, Ed.D., R.N. (New York Institute of Technology, Springfield Gardens, NY); Carlos Vallbona, M.D. (Baylor College of Medicine, Houston, TX); Howard S. Weiss, M.D., M.P.H. (Georgetown University Medical Center, Washington Hospital Center, Walter Reed Army Medical Center, Washington, DC); Jack P. Whisnant, M.D. (Mayo Clinic and Mayo Medical School, Rochester, MN); Laurie Willshire, M.P.H., R.N. (American Red Cross, Falls Church, VA); Gerald J. Wilson, M.A., M.B.A. (Citizens for Public Action on Blood Pressure and Cholesterol, Inc., Potomac, MD); Mary Winston, Ed.D., R.D. (American Heart Association, Dallas, TX); Jackson T. Wright, Jr., M.D., Ph.D. (Case Western Reserve University, Cleveland, OH)

## Additional Contributors

Jan N. Basile, M.D., F.A.C.P. (Veterans Administration Hospital, Charleston, SC); James I. Cleeman, M.D. (National Heart, Lung, and Blood Institute, Bethesda, MD); Darla E. Danford, M.P.H, D.Sc. (National Heart, Lung, and Blood Institute, Bethesda, MD); Richard A. Dart, M.D., F.A.C.P., F.C.C.P., F.A.H.A. (Marshfield Clinic, Marshfield, WI); Karen A. Donato, S.M., R.D. (National Heart, Lung, and Blood Institute, Bethesda, MD); Mark E. Dunlap, M.D. (Louis Stokes Cleveland VA Medical Center, Cleveland, OH); Brent M. Egan, M.D. (Medical University of South Carolina, Charleston, SC); William J. Elliott, M.D., Ph.D. (Rush University Medical Center, Chicago, IL); Bonita E. Falkner, M.D. (Thomas Jefferson University, Philadelphia, PA); John M. Flack, M.D., M.P.H. (Wayne State University School of Medicine, Detroit, MI); David Lee Gordon, M.D. (University of Miami School of Medicine, Miami, FL); Philip B. Gorelik, M.D., M.P.H., F.A.C.P. (Rush Medical College, Chicago, IL); Mary M. Hand, M.S.P.H., R.N (National Heart, Lung, and Blood Institute, Bethesda, MD); Linda A. Hershey, M.D., Ph.D. (VA WNY Healthcare System, Buffalo, NY); Norman M. Kaplan, M.D. (University of Texas Southwestern Medical School at Dallas, Dallas, TX); Daniel Levy, M.D. (National Heart, Lung, and Blood Institute, Framingham, MA); James W. Lohr, M.D. (VA WNY Healthcare System and SUNY Buffalo, Buffalo, NY); Vasilios Papademetriou, M.D., F.A.C.P., F.A.C.C. (Veterans Affairs Medical Center, Washington, DC); Thomas G. Pickering, M.D., D.Phil. (Mount Sinai Medical Center, New York, NY); Ileana L. Piña, M.D., F.A.C.C. (University Hospitals of Cleveland, Cleveland, OH); L. Michael Prisant, M.D., F.A.C.C., F.A.C.P. (Medical College of Georgia, Augusta, GA); Clive Rosendorff, M.D., Ph.D., F.R.C.P. (Veterans Affairs Medical Center, Bronx, NY); Virend K. Somers, M.D., Ph.D. (Mayo Clinic and Mayo Foundation, Rochester, MN); Ray Townsend, M.D. (University of Pennsylvania School of Medicine, Philadelphia, PA); Humberto Vidaillet, M.D. (Marshfield Clinic, Marshfield, WI); Donald G. Vidt, M.D. (Cleveland Clinic Foundation, Cleveland, OH); William White, M.D. (The University of Connecticut Health Center, Farmington, CT)

## Staff

Joanne Karimbakas, M.S., R.D. (American Institutes for Research Health Program, Silver Spring, MD)

We appreciate the assistance by: Carol Creech, M.I.L.S. and Gabrielle Gessner (American Institutes for Research Health Program, Silver Spring, MD).

## National High Blood Pressure Education Program Coordinating Committee Member Organizations

American Academy of Family Physicians

American Academy of Neurology

American Academy of Ophthalmology

American Academy of Physician Assistants

American Association of Occupational Health Nurses

American College of Cardiology

American College of Chest Physicians

American College of Occupational and Environmental Medicine

American College of Physicians-American Society of Internal Medicine

American College of Preventive Medicine

American Dental Association

American Diabetes Association

American Dietetic Association

American Heart Association

American Hospital Association

American Medical Association

American Nurses Association

American Optometric Association

American Osteopathic Association

American Pharmaceutical Association

American Podiatric Medical Association

American Public Health Association

American Red Cross

American Society of Health-System Pharmacists

American Society of Hypertension

American Society of Nephrology

Association of Black Cardiologists

Citizens for Public Action on High Blood Pressure and Cholesterol, Inc.

Hypertension Education Foundation, Inc.

International Society on Hypertension in Blacks

National Black Nurses Association, Inc.

National Hypertension Association, Inc.

National Kidney Foundation, Inc.

National Medical Association

National Optometric Association

National Stroke Association

National Heart, Lung, and Blood Institute Ad Hoc Committee on Minority Populations

Society for Nutrition Education

The Society of Geriatric Cardiology

## Federal Agencies

Agency for Health Care Research and Quality

Centers for Medicare & Medicaid Services

Department of Veterans Affairs

Health Resources and Services Administration

National Center for Health Statistics

National Heart, Lung, and Blood Institute

National Institute of Diabetes and Digestive and Kidney Diseases