# Classification of Blood Pressure

Table 3 provides a classification of BP for adults 18 years and older. The classification is based on the average of two or more properly measured, seated, BP readings on each of two or more office visits.

Table 3 Classification of blood pressure for adults

Blood Pressure | SBP | DBP
Classification | mmHg | mmHg
Normal | <120 | and <80
Prehypertension | 120–139 | or 80–89
Stage 1 Hypertension | 140–159 | or 90–99
Stage 2 Hypertension | ≥160 | or ≥100

SBP, systolic blood pressure; DBP, diastolic blood pressure

Prehypertension is not a disease category. Rather, it is a designation chosen to identify individuals at high risk of developing hypertension, so that both patients and clinicians are alerted to this risk and encouraged to intervene and prevent or delay the disease from developing. Individuals who are prehypertensive are not candidates for drug therapy based on their level of BP and should be firmly and unambiguously advised to practice lifestyle modification in order to reduce their risk of developing hypertension in the future (see Lifestyle Modifications). Moreover, individuals with prehypertension, who also have diabetes or kidney disease, should be considered candidates for appropriate drug therapy if a trial of lifestyle modification fails to reduce their BP to 130/80 mmHg or less.

This classification does not stratify hypertensive individuals by the presence or absence of risk factors or target organ damage in order to make different treatment recommendations, should either or both be present. JNC 7 suggests that all people with hypertension (stages 1 and 2) be treated. The treatment goal for individuals with hypertension and no other compelling conditions is <140/90 mmHg (see Compelling Indications). The goal for individuals with prehypertension and no compelling indications is to lower BP to normal levels with lifestyle changes, and prevent the progressive rise in BP using the recommended lifestyle modifications (see Lifestyle Modifications).

## Cardiovascular Disease Risk

The relationship between BP and risk of CVD events is continuous, consistent, and independent of other risk factors. The higher the BP, the greater the chance of heart attack, HF, stroke, and kidney diseases. The presence of each additional risk factor compounds the risk from hypertension as illustrated in figure 12.^20^ The easy and rapid calculation of a Framingham CHD risk score using published tables^21^ may assist the clinician and patient in demonstrating the benefits of treatment. Management of these other risk factors is essential and should follow the established guidelines for controlling these coexisting problems that contribute to overall cardiovascular risk.

Figure 12

Ten-year risk for coronary heart disease by systolic blood pressure and presence of other risk factors

CHD, coronary heart disease; HDL, high-density lipoprotein; LVH, left ventricular hypertrophy; SBP, systolic blood pressure

Source: Derived from Anderson KM, Wilson PWF, Odell PM, Kannel WB. An updated coronary risk profile. A statement for health professionals. Circulation 1991;83:356–62.