# Calibration, Maintenance, and Use of Blood Pressure Devices

The potential of mercury spillage contaminating the environment has led to the decreased use or elimination of mercury in sphygmomanometers as well as in thermometers.^52^ However, concerns regarding the accuracy of nonmercury sphygmomanometers have created new challenges for accurate BP determination.^53,54^ When mercury sphygmomanometers are replaced, the new equipment, including all home BP measurement devices, must be appropriately validated and checked regularly for accuracy.^55^

## Accurate Blood Pressure Measurement in the Office

The accurate measurement of BP is the sine qua non for successful management. The equipment—whether aneroid, mercury, or electronic—should be regularly inspected and validated. The operator should be trained and regularly retrained in the standardized technique, and the patient must be properly prepared and positioned.^4,^,^56,57^ The auscultatory method of BP measurement should be used.^58^ Persons should be seated quietly for at least 5 minutes in a chair (rather than on an exam table), with feet on the floor, and arm supported at heart level. Caffeine, exercise, and smoking should be avoided for at least 30 minutes prior to measurement. Measurement of BP in the standing position is indicated periodically, especially in those at risk for postural hypotension, prior to necessary drug dose or adding a drug, and in those who report symptoms consistent with reduced BP upon standing. An appropriately sized cuff (cuff bladder encircling at least 80 percent of the arm) should be used to ensure accuracy. At least two measurements should be made and the average recorded. For manual determinations, palpated radial pulse obliteration pressure should be used to estimate SBP—the cuff should then be inflated 20–30 mmHg above this level for the auscultatory determinations; the cuff deflation rate for auscultatory readings should be 2 mmHg per second. SBP is the point at which the first of two or more Korotkoff sounds is heard (onset of phase 1), and the disappearance of Korotkoff sound (onset of phase 5) is used to define DBP. Clinicians should provide to patients, verbally and in writing, their specific BP numbers and the BP goal of their treatment.

Followup of patients with various stages of hypertension is recommended as shown in table 4.

Table 4 Recommendations for followup based on initial blood pressure measurements for adults without acute end organ damage

Initial Blood Pressure (mmHg)^*^ | Followup Recommended^†^
Normal | Recheck in 2 years
Prehypertension | Recheck in 1 year^‡^
Stage 1 Hypertension | Confirm within 2 months^‡^
Stage 2 Hypertension | Evaluate or refer to source of care within 1 month. For those with higher pressures (e.g., >180/110 mmHg), evaluate and treat immediately or within 1 week depending on clinical situation and complications.

* If systolic and diastolic categories are different, follow recommendations for shorter time followup (e.g., 160/86 mmHg should be evaluated or referred to source of care within 1 month).

† Modify the scheduling of followup according to reliable information about past BP measurements, other cardiovascular risk factors, or target organ disease.

‡ Provide advice about lifestyle modifications (see Lifestyle Modifications).

## Ambulatory Blood Pressure Monitoring

Ambulatory blood pressure monitoring (ABPM) provides information about BP during daily activities and sleep.^59^ BP has a reproducible "circadian" profile, with higher values while awake and mentally and physically active, much lower values during rest and sleep, and early morning increases for 3 or more hours during the transition of sleep to wakefulness.^60^ These devices use either a microphone to measure Korotkoff sounds or a cuff that senses arterial waves using oscillometric techniques. Twenty-four hour BP monitoring provides multiple readings during all of a patient's activities. While office BP values have been used in the numerous studies that have established the risks associated with an elevated BP and the benefits of lowering BP, office measurements have some shortcomings. For example, a white-coat effect (increase in BP primarily in the medical care environment) is noted in as many as 20–35 percent of patients diagnosed with hypertension.^61^

Ambulatory BP values are usually lower than clinic readings. Awake hypertensive individuals have an average BP of >135/85 mmHg, and during sleep, >120/75 mmHg. The level of BP measurement using ABPM correlates better than office measurements with target organ injury.^15^ ABPM also provides a measure of the percentage of BP readings that are elevated, the overall BP load, and the extent of BP fall during sleep. In most people, BP drops by 10–20 percent during the night; those in whom such reductions are not present appear to be at increased risk for cardiovascular events. In addition, it was reported recently that ABPM patients whose 24-hour BP exceeded 135/85 mmHg were nearly twice as likely to have a cardiovascular event as those with 24-hour mean BPs <135/85 mmHg, irrespective of the level of the office BP.^62,63^

Indications for the use of ABPM are listed in table 5. Medicare reimbursement for ABPM is now provided to assess patients with suspected white-coat hypertension.

Table 5 Clinical situations in which ambulatory blood pressure monitoring may be helpful

- Suspected white-coat hypertension in patients with hypertension and no target organ damage; - Apparent drug resistance (office resistance); - Hypotensive symptoms with antihypertensive medication; - Episodic hypertension; - Autonomic dysfunction

## Self-Measurement

Self-monitoring of BP at home and work is a practical approach to assess differences between office and out-of-office BP prior to consideration of ABPM. For those whose out-of-office BPs are consistently <130/80 mmHg despite an elevated office BP, and who lack evidence of target organ disease, 24-hour monitoring or drug therapy can be avoided.

Self-measurement or ABPM may be particularly helpful in assessing BP in smokers. Smoking raises BP acutely, and the level returns to baseline about 15 minutes after stopping.