# Basis for Reclassification of Blood Pressure

Because of the new data on lifetime risk of hypertension and the impressive increase in the risk of cardiovascular complications associated with levels of BP previously considered to be normal, the JNC 7 report has introduced a new classification that includes the term "prehypertension" for those with BPs ranging from 120–139 mmHg systolic and/or 80–89 mmHg diastolic. This new designation is intended to identify those individuals in whom early intervention by adoption of healthy lifestyles could reduce BP, decrease the rate of progression of BP to hypertensive levels with age, or prevent hypertension entirely.

Another change in classification from JNC 6 is the combining of stage 2 and stage 3 hypertension into a single stage 2 category. This revision reflects the fact that the approach to the management of the former two groups is similar (table 2).

Table 2 Changes in blood pressure classification

JNC 6 Category | | JNC 7 Category
| SBP/DBP
Optimal | <120/80 | Normal
Normal | 120–129/80–84 | Prehypertension
Borderline | 130–139/85–89
Hypertension | ≥140/90 | Hypertension
Stage 1 | 140–159/90–99 | Stage 1
Stage 2 | 160–179/100–109 | Stage 2
Stage 3 | ≥180/110

DBP, diastolic blood pressure; JNC, Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure; SBP, systolic blood pressure

Sources: The Sixth Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Arch Intern Med 1997;157:2413–46.

The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. JAMA 2003;289:2560–71.