# Scheme Used for Classification of the Evidence

M Meta-analysis; use of statistical methods to combine the results from clinical trials

RA Randomized controlled trials; also known as experimental studies

RE Retrospective analyses; also known as case-control studies

F Prospective studies; also known as cohort studies, including historical or prospective followup studies

X Cross-sectional surveys; also known as prevalence studies

PR Previous review or position statements

C Clinical interventions (nonrandomized)

These symbols are appended to the citations in the reference list. The studies that provided evidence supporting the recommendations of this report were classified and reviewed by the staff and the Executive Committee. The classification scheme is from the JNC 6 report and other NHBPEP Working Group Reports.^3,^,^4,^,^6,9^