# References

These symbols are placed after the reference number for those citations provided in chapters 3 and 4 in the text. Some references may have more than one code depending on the component of the study cited, e.g., a randomized controlled trial having a long-term followup.

M meta-analyses—an analysis of a compendium of experimental studies;

Ra randomized controlled trials—also known as experimental studies;

Re retrospective analysis—also known as case control studies;

F prospective followup—also known as cohort studies, including historical cohort studies and long-term followup;

X cross-sectional population studies—also known as prevalence studies;

Pr previous review or position statements; and

C clinical interventions (nonrandomized).

1 Burt V L, Cutler J A, Higgins M, et al. Trends in the prevalence, awareness, treatment, and control of hypertension in the adult US population: data from the health examination surveys, 1960 to 1991. Hypertension. 1995;26:60-69. [pmid: 7607734].
2 Data calculated by National Heart, Lung, and Blood Institute staff, J. Cutler, principal investigator, January 1997.
3 Manton K G, Corder L, Stallard E. Chronic disability trends in elderly United States populations: 1982-1994. Proc Natl Acad Sci USA. 1997;94:2593-2598. [pmid: 9122240]. [pmcid: 20133].
4 Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure. The fifth report of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure (JNC V). Arch Intern Med. 1993;153:154-183. Pr. [pmid: 8422206].
5 National Heart, Lung, and Blood Institute. Fact Book Fiscal Year 1996. Bethesda, MD: U.S. Department of Health and Human Services, National Institutes of Health; 1997.
6 U.S. Renal Data System. USRDS 1997 Annual Report. Bethesda, MD: U.S. Department of Health and Human Services, National Institute of Diabetes and Digestive and Kidney Disease; 1997. X
7 Levy D, Larson M G, Vasan R S, Kannel W B, Ho K K L. The progression from hypertension to congestive heart failure. JAMA. 1996;275:1557-1562. F. [pmid: 8622246].
8 National Center for Health Statistics. Health, United States, 1996. Hyattsville, MD: Public Health Service; 1997.
9 Luepker R V, McGovern P G, Sprafka J M, Shahar E, Doliszny K M, Blackburn H. Unfavorable trends in the detection and treatment of hypertension: the Minnesota Heart Survey [abstract]. Circulation. 1995;91:938.
10 Meissner I, Whisnant J P, Sheps S, et al. Stroke prevention: assessment of risk in a community. The SPARC study, part I: blood pressure trends, treatment, and control [abstract]. Ann Neurol. 1997;42:433.
11 Brown R D Jr, Whisnant J P, Sicks J D, O'Fallon W M, Wiebers D O. Stroke incidence, prevalence, and survival: secular trends in Rochester, Minnesota, through 1989. Stroke. 1996;27:373-380. [pmid: 8610298].
12 Glynn R J, Brock D B, Harris T, et al. Use of antihypertensive drugs and trends in blood pressure in the elderly. Arch Intern Med. 1995;155:1855-1860. [pmid: 7677551].
13 U.S. Department of Health and Human Services. Healthy People 2000: National Health Promotion and Disease Prevention Objectives. Washington, DC: Public Health Service; DHHS publication no. (PHS) 91-50213; 1991.
14 Hall W D, Ferrario C M, Moore M A, et al. Hypertension-related morbidity and mortality in the southeastern United States. Am J Med Sci. 1997;313:195-206. Pr. [pmid: 9099149].
15 Banks J. National Heart, Lung, and Blood Institute Marketing Research Study on the Formatting, Dissemination, and Use of Clinical Practice Guidelines: Executive Overview. Bethesda, MD: National Heart, Lung, and Blood Institute; 1995.
16 Delbecq AL, Van de Ven AH, Gustafon DH. Group Techniques for Program Planning: A Guide to Nominal Group and Delphi Processes. Glenview, IL: Scott, Foresman and Company; 1975.
17 Last JM, Abramson JH (eds.) A Dictionary of Epidemiology, third edition. New York, NY: Oxford University Press; 1995.
18 Lever A F, Ramsay L E. Treatment of hypertension in the elderly. J Hypertens. 1995;13:571-579. [pmid: 7594412].
19 Guyatt G H, Sackett D L, Sinclair J C, Hayward R, Cook D J, Cook R J. for the Evidence-Based Medicine Working Group. Users' guides to the medical literature. IX. A method for grading health care recommendations. JAMA. 1995;274:1800-1804. [pmid: 7500513].
20 Zanchetti A, Mancia G. Editors' corner: strategies for antihypertensive treatment decisions: how to assess benefits?. J Hypertens. 1997;15:215-216. [pmid: 9468446].
21 Chatellier G, Ménard J. The absolute risk as a guide to influence the treatment decision-making process in mild hypertension. J Hypertens. 1997;15:217-219. [pmid: 9468447].
22 Linjer E, Hansson L. Underestimation of the true benefits of antihypertensive treatment: an assessment of some important sources of error. J Hypertens. 1997;15:221-225. [pmid: 9468448].
23 Gueyffier F, Froment A, Gouton M. New meta-analysis of treatment trials of hypertension: improving the estimate of therapeutic benefit. J Hum Hypertens. 1996;10:1-8. [pmid: 8642184].
24 Burt V L, Whelton P, Roccella E J, et al. Prevalence of hypertension in the US adult population: results from the third National Health and Nutrition Examination Survey, 1988-1991. Hypertension. 1995;25:305-313. X. [pmid: 7875754].
25 Fuster V, Pearson T A. 27^th^ Bethesda Conference: matching the intensity of risk factor management with the hazard for coronary disease events, September 14–15, 1995. J Am Coll Cardiol. 1996;27:957-1047. [pmid: 8609361].
26 National High Blood Pressure Education Program Working Group. National High Blood Pressure Education Program working group report on hypertension in the elderly. Hypertension. 1994;23:275-285. Pr. [pmid: 8125550].
27 Neaton J D, Wentworth D. for the Multiple Risk Factor Intervention Trial Research Group. Serum cholesterol, blood pressure, cigarette smoking, and death from coronary heart disease: overall findings and differences by age for 316,099 white men. Arch Intern Med. 1992;152:56-64. [pmid: 1728930].
28 National High Blood Pressure Education Program. Churches as an Avenue to High Blood Pressure Control. Bethesda, MD: U.S. Department of Health and Human Services, National Heart, Lung, and Blood Institute; NIH publication no. 92-2725; reprinted 1992.
29 National High Blood Pressure Education Program. National High Blood Pressure Education Program Working Group Report on Primary Prevention of Hypertension. Bethesda, MD: U.S. Department of Health and Human Services, National Heart, Lung, and Blood Institute; NIH publication no. 93-2669, 1993. Pr
30 National Heart, Lung, and Blood Institute. Finding Resources for Healthy Heart Programs at Work. Bethesda, MD: U.S. Department of Health and Human Services, National Institutes of Health; NIH publication no. 92-737; 1992.
31 National Heart, Lung, and Blood Institute. Minority Health Issues for an Emerging Majority: 4th National Forum on Cardiovascular Health, Pulmonary Disorders, and Blood Resources Proceedings. Sponsored by National Heart, Lung, and Blood Institute; NHLBI Ad Hoc Committee on Minority Populations; and National Medical Association, Washington, DC; June 26–27, 1992.
32 National Heart, Lung, and Blood Institute. The Sports Guide: NHLBI Planning Guide for Cardiovascular Risk Reduction Projects at Sporting Events. Bethesda, MD: U.S. Department of Health and Human Services, National Institutes of Health; NIH publication no. 95-3802; 1995.
33 University of Maryland School of Medicine. Control of Blood Pressure at the Workplace: University of Maryland School of Medicine. Baltimore, MD: University of Maryland; NTIS accession no. PB83-113381; 1982.
34 Westinghouse Health Systems. Demonstration Programs in Hypertension Control in the Work Setting: Volume I: Technical Report. Columbia, MD: Westing-house Health Systems; contract no. NO1-HV-82911; 1981.
35 Westinghouse Health Systems. Demonstration Programs in Hypertension Control in the Work Setting: Volume II: Exhibits and Appendices. Columbia, MD: Westinghouse Health Systems; NTIS accession no. PB83-113373; 1982.
36 Erfurt JC, Foote A. Hypertension Control in the Work Setting: The University of Michigan Ford Motor Company Demonstration Program. Springfield, VA: National Technical Information Service; NTIS accession no. PB83-113399; 1982.
37 Hill M N, Bone L R, Butz A M. Enhancing the role of community-health workers in research. Image: Journal of Nursing Scholarship. 1996;28:221-226. Pr.
38 Kotchen J M, McKean H E, Jackson-Thayer S, Moore R W, Straus R, Kotchen T A. Impact of a rural high blood pressure control program on hypertension control and cardiovascular disease mortality. JAMA. 1986;255:2177-2182. [pmid: 3959301].
39 Morisky D E, Levine D M, Green L W, Shapiro S, Russell R P, Smith C R. Five-year blood pressure control and mortality following health education for hypertensive patients. Am J Public Health. 1983;73:153-162. [pmid: 6849473].
40 Stamler J. Blood pressure and high blood pressure: aspects of risk. Hypertension. 1991;18(suppl I):I-95-I-107. F. [pmid: 1889862].
41 Flack J M, Neaton J, Grimm R Jr. for the Multiple Risk Factor Intervention Trial Research Group, et al. Blood pressure and mortality among men with prior myocardial infarction. Circulation. 1995;92:2437-2445. [pmid: 7586343].
42 Prisant L M, Alpert B S, Robbins C B, et al. American National Standard for nonautomated sphygmoma-nometers: summary report. Am J Hypertens. 1995;8:210-213. [pmid: 7755953].
43 Perloff D, Grim C, Flack J. for the Writing Group, et al. Human blood pressure determination by sphygmomanometry. Circulation. 1993;88:2460-2467. [pmid: 8222141].
44 American Society of Hypertension. Recommendations for routine blood pressure measurement by indirect cuff sphygmomanometry. Am J Hypertens. 1992;5:207-209. [pmid: 1599634].
45 Pickering T. for an American Society of Hypertension ad hoc panel. Recommendations for the use of home (self) and ambulatory blood pressure monitoring. Am J Hypertens. 1995;9:1-11. Pr. [pmid: 8834700].
46 Mancia G, Sega R, Milesi C, Cesana G, Zanchetti A. Blood-pressure control in the hypertensive population. Lancet. 1997;349:454-457. [pmid: 9040574].
47 Appel L J, Stason W B. Ambulatory blood pressure monitoring and blood pressure self-measurement in the diagnosis and management of hypertension. Ann Intern Med. 1993;118:867-882. [pmid: 8093115].
48 Tsuji I, Imai Y, Nagai K, et al. Proposal of reference values for home blood pressure measurement: prognostic criteria based on a prospective observation of the general population in Ohasama, Japan. Am J Hypertens. 1997;10:409-418. [pmid: 9128207].
49 O'Brien E, Petrie J, Littler W, et al. The British Hypertension Society protocol for the evaluation of automated and semi-automated blood pressure measuring devices with special reference to ambulatory systems. J Hypertens. 1990;8:607-619. [pmid: 2168451].
50 White W B, Berson A S, Robbins C, et al. National standard for measurement of resting and ambulatory blood pressures with automated sphygmomanometers. Hypertension. 1993;21:504-509. [pmid: 8458649].
51 Nesselroad J M, Flacco V A, Phillips D M, Kruse J. Accuracy of automated finger blood pressure devices. Fam Med. 1996;28:189-192. [pmid: 8900551].
52 Consumer Reports. Blood-pressure monitors: convenience doesn't equal accuracy. Consumer Rep 1996; 61:50,53–55.
53 Sternberg H, Rosenthal T, Shamiss A, Green M. Altered circadian rhythm of blood pressure in shift workers. J Hum Hypertens. 1995;9:349-353. [pmid: 7623372].
54 Perloff D, Sokolow M, Cowan R. The prognostic value of ambulatory blood pressures. JAMA. 1983;249:2792-2798. [pmid: 6842787].
55 Perloff D, Sokolow M, Cowan R M, Juster R P. Prognostic value of ambulatory blood pressure measurements: further analyses. J Hypertens. 1989;7(suppl 3):S3-S10.
56 Verdecchia P, Porcellati C, Schillaci G, et al. Ambulatory blood pressure: an independent predictor of prognosis in essential hypertension. Hypertension. 1994;24:793-801. [pmid: 7995639].
57 Klein R, Klein B E K, Moss S E, Wang Q. Hypertension and retinopathy, arteriolar narrowing, and arteriovenous nicking in a population. Arch Ophthalmol. 1994;112:92-98. [pmid: 8285901].
58 Newman A B, Sutton-Tyrell K, Vogt M T, Kuller L H. Morbidity and mortality in hypertensive adults with a low ankle/arm blood pressure index. JAMA. 1993;270:487-489. [pmid: 8147959].
59 Ward R. Familial aggregation and genetic epidemiology of blood pressure. In: Laragh JH, Brenner BM, (eds.). Hypertension: Pathophysiology, Diagnosis, and Management. New York, NY: Raven Press; 1990:81–100.
60 Lifton R P, Dluhy R G, Powers M, et al. A chimaeric 11-ß-hydroxylase/aldosterone synthase gene causes glucocorticoid-remediable aldosteronism and human hypertension. Nature. 1992;355:262-265. [pmid: 1731223].
61 Lander E S, Schork N J. Genetic dissection of complex traits. Science. 1994;265:2037-2048. [pmid: 8091226].
62 WHO Expert Committee on Hypertension Control. Hypertension Control: Report of a WHO Expert Committee, WHO Technical Report Series no. 862. Geneva, Switzerland: World Health Organization; 1996.
63 Anderson K M, Wilson P W F, Odell P M, Kannel W B. An updated coronary risk profile: a statement for health professionals. Circulation. 1991;83:356-362. [pmid: 1984895].
64 Kannel W B. Blood pressure as a cardiovascular risk factor: prevention and treatment. JAMA. 1996;275:1571-1576. F. [pmid: 8622248].
65 Levy D. A multifactoral approach to coronary disease risk assessment. Clin Exp Hypertens. 1993;15:1077-1086. [pmid: 8268875].
66 American Heart Association. Welcome to the Coronary Heart Disease Risk Assessment [Web page]. http://www.amhrt.org/risk/index.html.
67 Thürmer H L, Lund-Larsen P G, Tverdal A. Is blood pressure treatment as effective in a population setting as in controlled trials? Results from a prospective study. J Hypertens. 1994;12:481-490. F. [pmid: 8064174].
68 Stamler R, Stamler J, Gosch F C, et al. Primary prevention of hypertension by nutritional-hygienic means: final report of a randomized, controlled trial. JAMA. 1989;262:1801-1807. Ra. [pmid: 2778913].
69 Stamler J, Caggiula A W, Grandits G A. Chapter 12. Relation of body mass and alcohol, nutrient, fiber, and caffeine intakes to blood pressure in the special intervention and usual care groups in the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65(suppl):338S-365S. F. [pmid: 8988947].
70 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. 1990;150:153-162. Ra. [pmid: 2404477].
71 Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels: results of the Trials of Hypertension Prevention, phase I. JAMA. 1992;267:1213-1220. Ra. [pmid: 1586398].
72 Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure: the Trials of Hypertension Prevention, phase II. Arch Intern Med. 1997;157:657-667. Ra. [pmid: 9080920].
73 Appel L J, Moore T J, Obarzanek E. for the DASH Collaborative Research Group, et al. A clinical trial of the effects of dietary patterns on blood pressure. N Engl J Med. 1997;336:1117-1124. Ra. [pmid: 9099655].
74 Du X, Cruickshank K, McNamee R, et al. Casecontrol study of stroke and the quality of hypertension control in north west England. BMJ. 1997;314:272-276. Re. [pmid: 9022492].
75 Lazarus J M, Bourgoignie J J, Buckalew V M. for the Modification of Diet in Renal Disease Study Group, et al. Achievement and safety of a low blood pressure goal in chronic renal disease: the Modification of Diet in Renal Disease Study Group. Hypertension. 1997;29:641-650. Ra, F. [pmid: 9040451].
76 Krumholz H M, Parent E M, Tu N, et al. Readmission after hospitalization for congestive heart failure among medicare beneficiaries. Arch Intern Med. 1997;157:99-104. F. [pmid: 8996046].
77 Neaton J D, Grimm R H Jr, Prineas R J. for the Treatment of Mild Hypertension Study Research Group, et al. Treatment of Mild Hypertension Study: final results. JAMA. 1993;270:713-724. C, Ra. [pmid: 8336373].
78 Singer D R J, Markandu N D, Cappuccio F P, Miller M A, Sagnella G A, MacGregor G A. Reduction of salt intake during converting enzyme inhibitor treatment compared with addition of a thiazide. Hypertension. 1995;25:1042-1044. Ra. [pmid: 7737713].
79 Pouliot M C, Després J P, Lemieux S, et al. Waist circumference and abdominal sagittal diameter: best simple anthropometric indexes of abdominal visceral adipose tissue accumulation and related cardiovascular risk in men and women. Am J Cardiol. 1994;73:460-468. X. [pmid: 8141087].
80 Whelton P K, Applegate W B, Ettinger W H, et al. Efficacy of weight loss and reduced sodium intake in the Trial of Nonpharmacologic Interventions in the Elderly (TONE) [abstract]. Circulation. 1996;94(suppl I):I-178. Ra.
81 U.S. Department of Health and Human Services. Physical Activity and Health: A Report of the Surgeon General. Atlanta, GA: Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion; 1996. Pr
82 Connolly H M, Crary J L, McGoon M D, et al. Valvular heart disease associated with fenfluramine-phentermine. New Engl J Med. 1997;337:581-588. [pmid: 9271479].
83 Abenhaim L, Moride Y, Brenot F, et al. Appetite-suppressant drugs and the risk of primary pulmo-nary hypertension. N Engl J Med. 1996;335:609-616. Re. [pmid: 8692238].
84 Puddey I B, Parker M, Beilen L J, Vandongen R, Masarei J R L. Effects of alcohol and caloric restrictions on blood pressure and serum lipids in overweight men. Hypertension. 1992;20:533-541. Ra. [pmid: 1356922].
85 Gill J S, Shipley M J, Tsementzis S A, et al. Alcohol consumption—a risk factor for hemorrhagic and non-hemorrhagic stroke. Am J Med. 1991;90:489-497. Re. [pmid: 2012089].
86 Frezza M, di Padova C, Pozzato G, Terpin M, Baraona E, Lieber C S. High blood alcohol levels in women: the role of decreased gastric alcohol dehydrogenase activity and first-pass metabolism. New Engl J Med. 1990;322:95-99. C. [pmid: 2248624].
87 U.S. Department of Agriculture and U.S. Department of Health and Human Services. Nutrition and Your Health: Dietary Guidelines for Americans, Fourth edition. Home and Garden Bulletin No. 232. Washington, DC: U.S. Department of Agriculture; 1995.
88 Paffenbarger R S Jr, Hyde R T, Wing A L, Lee I M, Jung D L, Kampert J B. The association of changes in physical-activity level and other lifestyle characteristics with mortality among men. N Engl J Med. 1993;328:538-545. F. [pmid: 8426621].
89 Kokkinos P F, Narayan P, Colleran J A, et al. Effects of regular exercise on blood pressure and left ventricular hypertrophy in African-American men with severe hypertension. N Engl J Med. 1995;333:1462-1467. Ra. [pmid: 7477146].
90 Blair S N, Goodyear N N, Gibbons L W, Cooper K H. Physical fitness and incidence of hypertension in healthy normotensive men and women. JAMA. 1984;252:487-490. F. [pmid: 6737638].
91 Weinberger M H. Salt sensitivity of blood pressure in humans. Hypertension. 1996;27(part 2):481-490. Pr. [pmid: 8613190].
92 Elliott P, Stamler J, Nichols R. for the Intersalt Cooperative Research Group, et al. Intersalt revisited: further analyses of 24 hour sodium excretion and blood pressure within and across populations. BMJ. 1996;312:1249-1253. X. [pmid: 8634612].
93 Cutler J A, Follmann D, Allender P S. Randomized trials of sodium reduction: an overview. Am J Clin Nutr. 1997;65(suppl):643S-651S. M. [pmid: 9022560].
94 Midgley J P, Matthew A G, Greenwood C M T, Logan A G. Effect of reduced dietary sodium on blood pressure: a meta-analysis of randomized controlled trials. JAMA. 1996;275:1590-1597. M. [pmid: 8622251].
95 Alderman M H, Madhavan S, Cohen H, Sealey J E, Laragh J H. Low urinary sodium is associated with greater risk of myocardial infarction among treated hypertensive men. Hypertension. 1995;25:1144-1152. F. [pmid: 7768554].
96 Devine A, Criddle R A, Dick I M, Kerr D A, Prince R L. A longitudinal study of the effect of sodium and calcium intakes on regional bone density in postmenopausal women. Am J Clin Nutr. 1995;62:740-745. F. [pmid: 7572702].
97 Ram C V S, Garrett B N, Kaplan N M. Moderate sodium restriction and various diuretics in the treatment of hypertension: effects of potassium wastage and blood pressure control. Arch Intern Med. 1981;141:1015-1019. Ra. [pmid: 7247587].
98 Antonios T F T, MacGregor G A. Salt—more adverse effects. Lancet. 1996;348:250-251. Pr. [pmid: 8684205].
99 Cirillo M, Laurenzi M, Panarelli W, Stamler J. for the Gubbio Population Study Research Group. Urinary sodium to potassium ratio and urinary stone disease. Kidney Int. 1994;46:1133-1139. F. [pmid: 7861708].
100 Liebson P R, Grandits G A, Dianzumba S. for the Treatment of Hypertension Study Research Group, et al. Comparison of five antihypertensive monotherapies and placebo for change in left ventricular mass in patients receiving nutritional-hygienic therapy in the Treatment of Mild Hypertension Study (TOMHS). Circulation. 1995;91:698-706. Ra. [pmid: 7828296].
101 Messerli F H, Schmieder R E, Weir M R. Salt—a perpetrator of hypertensive target organ disease?. Arch Intern Med. 1997;157:2449-2452. Pr. [pmid: 9385295].
102 Whelton P K, He J, Cutler J A, et al. Effects of oral potassium on blood pressure: meta- analysis of randomized controlled clinical trials. JAMA. 1997;277:1624-1632. M. [pmid: 9168293].
103 Cappuccio F P, Elliott P, Allender P S, Pryer J, Follman D A, Cutler J A. Epidemiologic association between dietary calcium intake and blood pressure: a meta-analysis of published data. Am J Epidemiol. 1995;142:935-945. F. [pmid: 7572974].
104 Allender P S, Cutler J A, Follmann D, Cappuccio F P, Pryer J, Elliott P. Dietary calcium and blood pressure: a meta-analysis of randomized clinical trials. Ann Intern Med. 1996;124:825-831. M. [pmid: 8610952].
105 Toft I, Bønaa K H, Ingebretsen O C, Nordøy A, Jenssen T. Effects of n-3 polyunsaturated fatty acids on glucose homeostasis and blood pressure in essential hypertension a randomized, controlled trial. Ann Intern Med. 1995;123:911-918. Ra. [pmid: 7486485].
106 Obarzanek E, Velletri P A, Cutler J A. Dietary protein and blood pressure. JAMA. 1996;275:1598-1603. Pr. [pmid: 8622252].
107 Stamler J, Elliott P, Kesteloot H, et al. Inverse relation of dietary protein markers with blood pressure: findings for 10,020 men and women in the INTERSALT study. Circulation. 1996;94:1629-1634. F. [pmid: 8840854].
108 van Montfrans G A, Karemaker J M, Wieling W, Dunning A J. Relaxation therapy and continuous ambulatory blood pressure in mild hypertension: a controlled study. BMJ. 1990;300:1368-1372. Ra. [pmid: 2196946].
109 Alexander C N, Schneider R H, Staggers F, et al. Trial of stress reduction for hypertension in older African Americans. II. Sex and risk subgroup analysis. Hypertension. 1996;28:228-237. Ra. [pmid: 8707387].
110 Greenberg G, Thompson S G, Brennan P J. The relationship between smoking and the response to antihypertensive treatment in mild hypertensives in the Medical Research Council's trial of treatment. Int J Epidemiol. 1987;16:25-30. F. [pmid: 3553048].
111 U.S. Department of Health and Human Services. The Health Benefits of Smoking Cessation: A Report of the Surgeon General. Rockville, MD: Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health; DHHS publication no. (CDC) 90-8416; 1990. Pr
112 Agency for Health Care Policy and Research. You Can Quit Smoking: Consumer Guide. Washington, DC: U.S. Department of Health and Human Services; AHCPR publication no. 96-0695; 1996.
113 American Heart Association. Calling It Quits. Dallas, TX: American Heart Association; 1984.
114 American Lung Association. Helping Smokers Get Ready To Quit. New York, NY: American Lung Association; 1991.
115 U.S. Department of Health and Human Services. “I Quit”—What To Do When You're Sick of Smoking, Chewing, or Dipping. Atlanta, GA: Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion; 1997.
116 Khoury Z, Comans P, Keren A, Lerer T, Gavish A, Tzivoni D. Effects of transdermal nicotine patches on ambulatory ECG monitoring findings: a double-blind study in healthy smokers. Cardiovasc Drugs Ther. 1996;10:179-184. Re. [pmid: 8842510].
117 Stamler J, Rains-Clearman D, Lenz-Litzow K, Tillotson J L, Grandits G A. Chapter 14. Relation of smoking at baseline and during trial years 1–6 to food and nutrient intakes and weight in the special intervention and usual care groups in the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65(suppl):374S-402S. F. [pmid: 8988949].
118 Psaty B M, Smith N L, Siscovick D S, et al. Health outcomes associated with antihypertensive therapies used as first-line agents: a systematic review and meta-analysis. JAMA. 1997;277:739-745. M. [pmid: 9042847].
119 Moser M, Hebert P R. Prevention of disease progression, left ventricular hypertrophy and congestive heart failure in hypertension treatment trials. J Am Coll Cardiol. 1996;27:1214-1218. Pr. [pmid: 8609345].
120 MacMahon S, Rodgers A. The effects of blood pressure reduction in older patients: an overview of five randomized controlled trials in elderly hypertensives. Clin Exp Hypertens. 1993;15:967-978. M. [pmid: 8268901].
121 Frishman W H, Bryzinski B S, Coulson L R, et al. A multifactorial trial design to assess combination therapy in hypertension: treatment with bisoprolol and hydrochlorothiazide. Arch Intern Med. 1994;154:1461-1468. Ra. [pmid: 8018001].
122 Epstein M, Bakris G. Newer approaches to antihypertensive therapy: use of fixed-dose combination therapy. Arch Intern Med. 1996;156:1969-1978. Pr. [pmid: 8823150].
123 Gradman A H, Cutler N R, Davis P J, Robbins J A, Weiss R J, Wood B C. for the Enalapril-Felodipine ER Factorial Study Group. Combined enalapril and felodipine extended release (ER) for systemic hypertension. Am J Cardiol. 1997;79:431-435. Ra. [pmid: 9052345].
124 Grossman E, Messerli F H, Grodzicki T, Kowey P. Should a moratorium be placed on sublingual nifedipine capsules given for hypertensive emergencies and pseudoemergencies?. JAMA. 1996;276:1328-1331. Pr. [pmid: 8861992].
125 Furberg C D, Psaty B M, Meyer J V. Nifedipine: dose-related increase in mortality in patients with coronary heart disease. Circulation. 1995;92:1326-1331. M. [pmid: 7648682].
126 Ad Hoc Subcommittee of the Liaison Committee of the World Health Organisation and the Interna-tional Society of Hypertension. Effects of calcium antagonists on the risks of coronary heart disease, cancer and bleeding. J Hypertens. 1997;15:105-115. Pr. [pmid: 9469785].
127 Psaty B M, Furberg C D. Clinical implications of the WHO/ISH statement on calcium antagonists. J Hypertens. 1997;15:1197-1200. [pmid: 9383166].
128 Gueyffier F, Boutitie F, Boissel J P. for the INDANA Investigators, et al. Effect of antihypertensive drug treatment on cardiovascular outcomes in women and men: a meta-analysis of individual patient data from randomized, controlled trials. Ann Intern Med. 1997;126:761-767. M. [pmid: 9148648].
129 Materson B J, Reda D J, Cushman W C. for the Department of Veterans Affairs Cooperative Study Group on Antihypertensive Agents, et al. Single-drug therapy for hypertension in men: a comparison of six antihypertensive agents with placebo. N Engl J Med. 1993;328:914-921. Ra. [pmid: 8446138].
130 Grimm R H Jr, Grandits G A, Cutler J A. for the TOMHS Research Group, et al. Relationships of quality-of-life measures to long-term lifestyle and drug treatment in the Treatment of Mild Hypertension Study. Arch Intern Med. 1997;157:638-648. Ra. [pmid: 9080918].
131 Edelson J T, Weinstein M C, Tosteson A N A, Williams L, Lee T H, Goldman L. Long-term cost-effectiveness of various initial monotherapies for mild to moderate hypertension. JAMA. 1990;263:407-413. Pr. [pmid: 2136759].
132 Jönsson B G. Cost-benefit of treating hypertension. J Hypertens. 1994;12(suppl 10):S65-S70. Pr.
133 Johannesson M. The cost effectiveness of hypertension treatment in Sweden. Pharmaco Economics. 1995;7:242-250. Pr.
134 Kaplan N M, Gifford R W Jr. Choice of initial therapy for hypertension. JAMA. 1996;275:1577-1580. Pr. [pmid: 8622249].
135 Materson B J, Reda D J, Preston R A. for the Department of Veterans Affairs Cooperative Study Group on Antihypertensive Agents., et al. Response to a second single antihypertensive agent used as mono-therapy for hypertension after failure of the initial drug. Arch Intern Med. 1995;155:1757-1762. F. [pmid: 7654109].
136 Farnett L, Mulrow C D, Linn W D, Lucey C R, Tuley M R. The J-curve phenomenon and the treatment of hypertension: is there a point beyond which pressure reduction is dangerous?. JAMA. 1991;265:489-495. Pr. [pmid: 1824642].
137 Coope J, Warrender T S. Randomised trial of treatment of hypertension in elderly patients in primary care. Br Med J. 1986;293:1145-1151. F. [pmid: 3094811].
138 Staessen J, Bulpitt C, Clement D, et al. Relation between mortality and treated blood pressure in elderly patients with hypertension: report of the European Working Party on High Blood Pressure in the Elderly. Br Med J. 1989;298:1552-1556. F. [pmid: 2503114].
139 Madhavan S, Ooi W L, Cohen H, Alderman M H. Relation of pulse pressure and blood pressure reduction to the incidence of myocardial infarction. Hypertension. 1994;23:395-401. F. [pmid: 8125567].
140 Staessen J A, Fagard R, Thijs L. for the Systolic Hypertension—Europe (Syst-Eur) Trial Investigators., et al. Morbidity and mortality in the placebo-controlled European Trial on Isolated Systolic Hypertension in the Elderly. Lancet. 1997;350:757-764. Ra. [pmid: 9297994].
141 Collins R, MacMahon S. Blood pressure, antihypertensive drug treatment and the risks of stroke and of coronary heart disease. Br Med Bull. 1994;50:272-298. Pr. [pmid: 8205459].
142 Systolic Hypertension in the Elderly Program Cooperative Research Group. Implications of the Systolic Hypertension in the Elderly Program. Hypertension. 1993;21:335-343. Ra. [pmid: 8478043].
143 Miller N H, Hill M, Kottke T, Ockene I S. The multilevel compliance challenge: recommendations for a call to action; a statement for healthcare professionals. Circulation. 1997;95:1085-1090. Pr. [pmid: 9054774].
144 Schultz J F, Sheps S G. Management of patients with hypertension: a hypertension clinic model. Mayo Clin Proc. 1994;69:997-999. Pr. [pmid: 7934199].
145 Setaro J F, Black H R. Refractory hypertension. N Engl J Med. 1992;327:543-547. Pr. [pmid: 1635569].
146 U.S. Bureau of the Census, Population Division. Estimates From the 1990 Census. Washington, DC: U.S. Bureau of the Census 1996. X
147 Fang J, Madhavan S, Alderman M H. The association between birthplace and mortality from cardiovascular causes among black and white residents of New York City. N Engl J Med. 1996;335:1545-1551. F. [pmid: 8900086].
148 Havas S, Sherwin R. Putting it all together: summary of the NHLBI Workshop on the Epidemiology of Hypertension in Hispanic American, Native American, and Asian/Pacific Islander American Populations. Public Health Rep. 1996;3(suppl 2):77-79. Pr.
149 Chen M F, Chen C C, Chen W J, Wu C C, Liau C S, Lee Y T. Dose titration study of isradipine in Chinese patients with mild to moderate essential hypertension. Cardiovasc Drugs Ther. 1993;7:133-138. C. [pmid: 8485068].
150 Chen M F, Yang C Y, Chen W J, et al. A double-blind comparison of once-daily metoprolol controlled-release and atenolol in the treatment of Chinese patients with mild to moderate hypertension. Cardiovasc Drugs Ther. 1995;9:401-406. X. [pmid: 8527349].
151 Enas E A, Garg A, Davidson M A, Nair V M, Huet B A, Yusuf S. Coronary heart disease and its risk factors in first-generation immigrant Asian Indians to the United States of America. Indian Heart J. 1996;48:343-353. X. [pmid: 8908818].
152 Howard B V, Lee E T, Yeh J L, et al. Hypertension in adult American Indians: the Strong Heart Study. Hypertension. 1996;28:256-264. X. [pmid: 8707391].
153 Winkleby M A, Kraemer H, Lin J, Jatulis D, Fortmann S P. Sociodemographic influences on Hispanic-white differences in blood pressure. Public Health Rep. 1996;111(suppl 2):30-32. X. [pmid: 8898768].
154 Singh G K, Kochanek K D, MacDorman M F. Advance report of final mortality statistics, 1994. Mon Vital Stat Rep. 1996;45(3, suppl):1-76. X.
155 Klag M J, Whelton P K, Randall B L, Neaton J D, Brancati F L, Stamler J. End-stage renal disease in African-American and white men: 16-year MRFIT findings. JAMA. 1997;277:1293-1298. F. [pmid: 9109467].
156 Hypertension Detection and Follow-up Program Cooperative Group. Five-year findings of the Hypertension Detection and Follow-up Program: mortality by race-sex and blood pressure level: a further analysis. J Community Health. 1984;9:314-327. Ra. [pmid: 6480895].
157 Ooi W L, Budner N S, Cohen H, Madhavan S, Alderman M H. Impact of race on treatment response and cardiovascular disease among hypertensives. Hypertension. 1989;14:227-234. F. [pmid: 2767755].
158 Townsend R R, DiPette D J, Goodman R, et al. Combined α/β-blockade versus α_1_-selective blockade in essential hypertension in black and white patients. Clin Pharmacol Ther. 1990;48:665-675. Ra. [pmid: 2249378].
159 SOLVD Investigators. Effect of enalapril on survival in patients with reduced left ventricular ejection fractions and congestive heart failure. N Engl J Med. 1991;325:293-302. Ra. [pmid: 2057034].
160 National High Blood Pressure Education Program Working Group on Hypertension Control in Children and Adolescents. Update on the 1987 task force report on high blood pressure in children and adolescents: a working group report from the National High Blood Pressure Education Program. Pediatrics. 1996;98:649-658. Pr. [pmid: 8885941].
161 Woods J W. Oral contraceptives and hypertension. Hypertension. 1988;11(suppl II):II-11-II-15. Pr. [pmid: 3280486].
162 Sibai B M. Treatment of hypertension in pregnant women. New Engl J Med. 1996;335:257-265. Pr. [pmid: 8657243].
163 Lindheimer M D. Pre-eclampsia—eclampsia 1996: preventable? Have disputes on its treatment been resolved?. Curr Opin Nephrol Hypertens. 1996;5:452-458. Pr. [pmid: 8937816].
164 Levine R J. for the CPEP Study Group. Calcium for preeclampsia (CPEP): a double-blind, placebocontrolled trial in healthy nulliparas. N Engl J Med. 1997;337:69-76. Pr. [pmid: 9211675].
165 National High Blood Pressure Education Program Working Group on High Blood Pressure in Pregnancy. National High Blood Pressure Education Program working group report on high blood pressure in pregnancy. Am J Obstet Gynecol. 1990;163:1689-1712. Pr.
166 Writing Group for the PEPI Trial. Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women: the Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. JAMA. 1995;273:199-208. Ra. [pmid: 7807658].
167 Sagie A, Larson M G, Levy D. The natural history of borderline isolated systolic hypertension. N Engl J Med. 1993;329:1912-1917. F. [pmid: 8247055].
168 Messerli F H. Osler's maneuver, pseudohypertension, and true hypertension in the elderly. Am J Med. 1986;80:906-910. [pmid: 2939716].
169 Wiinberg N, Høegholm A, Christensen H R, et al. 24-h ambulatory blood pressure in 352 normal Danish subjects, related to age and gender. Am J Hypertens. 1995;8:978-986. X. [pmid: 8845079].
170 Ooi W L, Barrett S, Hossain M, Kelley-Gagnon M, Lipsitz L A. Patterns of orthostatic blood pressure change and their clinical correlates in a frail, elderly population. JAMA. 1997;277:1299-1304. X. [pmid: 9109468].
171 SHEP Cooperative Research Group. Prevention of stroke by antihypertensive drug treatment in older persons with isolated systolic hypertension: final results of the Systolic Hypertension in the Elderly Program (SHEP). JAMA. 1991;265:3255-3264. Ra. [pmid: 2046107].
172 MRC Working Party. Medical Research Council trial of treatment of hypertension in older adults: principal results. BMJ. 1992;304:405-412. Ra, F. [pmid: 1445513].
173 Dahlöf B, Lindholm L H, Hansson L, Scherstén B, Ekbom T, Wester P O. Morbidity and mortality in the Swedish Trial in Old Patients with Hypertension (STOP-Hypertension). Lancet. 1991;338:1281-1285. Ra. [pmid: 1682683].
174 Kostis J B, Davis B R, Cutler J, et al. Prevention of heart failure by antihypertensive drug treatment in older persons with isolated systolic hypertension. JAMA. 1997;278:212-216. Ra. [pmid: 9218667].
175 National Institute of Neurological Disorders and Stroke rt-PA Stroke Study Group. Tissue plasminogen activator for acute ischemic stroke. N Engl J Med. 1995;333:1581-1587. C. [pmid: 7477192].
176 Hennekens C H, Albert C M, Godfried S L, Gaziano J M, Buring J E. Adjunctive drug therapy of acute myocardial infarction—evidence from clinical trials. N Engl J Med. 1996;335:1660-1667. Pr. [pmid: 8929364].
177 Smith S C Jr, Blair S N, Criqui M H. for the Secondary Prevention Panel, et al. Preventing heart attack and death in patients with coronary disease. J Am Coll Cardiol. 1995;26:292-294. Pr. [pmid: 7797767].
178 Alderman M H, Cohen H, Roqué R, Madhavan S. Effect of long-acting and short-acting calcium antagonists on cardiovascular outcomes in hypertensive patients. Lancet. 1997;349:594-598. Re. [pmid: 9057730].
179 Psaty B M, Heckbert S R, Koepsell T D, et al. The risk of myocardial infarction associated with antihypertensive drug therapies. JAMA. 1995;274:620-625. Re. [pmid: 7637142].
180 Ryan T J, Anderson J L, Antman E M, et al. ACC/AHA guidelines for the management of patients with acute myocardial infarction: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Management of Acute Myocardial Infarction). J Am Coll Cardiol. 1996;28:1328-1428. Pr. [pmid: 8890834].
181 Gibson R S, Boden W E. Calcium channel antagonists: friend or foe in postinfarction patients?. Am J Hypertens. 1996;9:172S-176S. Pr. [pmid: 8968429].
182 Koren M J, Devereux R B, Casale P N, Savage D D, Laragh J H. Relation of left ventricular mass and geometry to morbidity and mortality in uncomplicated essential hypertension. Ann Intern Med. 1991;114:345-352. F. [pmid: 1825164].
183 Liao Y, Cooper R S, McGee D L, Mensah G A, Ghali J K. The relative effects of left ventricular hypertrophy, coronary artery disease, and ventricular dysfunction on survival among black adults. JAMA. 1995;273:1592-1597. F. [pmid: 7745772].
184 Devereux R B. Do antihypertensive drugs differ in their ability to regress left ventricular hypertrophy?. Circulation. 1997;95:1983-1985. Pr. [pmid: 9133501].
185 Gottdiener J S, Reda D J, Massie B M, Materson B J, Williams D W, Anderson R J. for the VA Cooperative Study Group on Antihypertensive Agents. Effect of single-drug therapy on reduction of left ventricular mass in mild to moderate hypertension: comparison of six antihypertensive agents; the Department of Veterans Affairs Cooperative Study Group on Anti-hypertensive Agents. Circulation. 1997;95:2007-2014. Ra. [pmid: 9133508].
186 Levy D, Salomon M, D'Agostino R B, Belanger A J, Kannel W B. Prognostic implications of baseline electrocardiographic features and their serial changes in subjects with left ventricular hypertrophy. Circulation. 1994;90:1786-1793. F. [pmid: 7923663].
187 Devereux R B, Agabiti-Rosei E, Dahlöf B, et al. Regression of left ventricular hypertrophy as a surrogate end-point for morbid events in hypertension treatment trials. J Hypertens. 1996;14(suppl 2):S95-S102. Pr.
188 Frohlich ED. Pathophysiology of systemic arterial hypertension. In: Schlant RC, Alexander RW, O'Rourke RA, Roberts R, Sonnenblick EH (eds.). Hurst's The Heart, eighth edition. New York, NY: McGraw-Hill; 1993:1391–1401. Pr
189 Sheps S G, Frohlich E D. Limited echocardiography for hypertensive left ventricular hypertrophy. Hypertension. 1997;29:560-563. Pr. [pmid: 9040438].
190 Vasan R S, Levy D. The role of hypertension in the pathogenesis of heart failure: a clinical mechanistic overview. Arch Intern Med. 1996;156:1789-1796. Pr. [pmid: 8790072].
191 Pfeffer M A, Braunwald E, Moyé L A. for the SAVE Investigators, et al. Effect of captopril on mortality and morbidity in patients with left ventricular dysfunction after myocardial infarction: results of the Survival and Ventricular Enlargement Trials. N Engl J Med. 1992;327:669-677. Ra. [pmid: 1386652].
192 Garg R, Yusuf S. for the Collaborative Group on ACE Inhibitor Trials. Overview of randomized trials of angiotensin-converting enzyme inhibitors on mortality and morbidity in patients with heart failure. JAMA. 1995;273:1450-1456. M. [pmid: 7654275].
193 Cohn J N, Archibald D G, Ziesche S, et al. Effect of vasodilator therapy on mortality in chronic congestive heart failure. Results of a Veterans Administra-tion Cooperative Study. New Engl J Med. 1986;314:1547-1542. Ra. [pmid: 3520315].
194 Packer M, Bristow M R, Cohn J N. for the U.S. Carvedilol Heart Failure Study Group, et al. The effect of carvedilol on morbidity and mortality in patients with chronic heart failure. N Engl J Med. 1996;334:1349-1355. Ra. [pmid: 8614419].
195 Australia/New Zealand Heart Failure Research Collaborative Group. Randomised, placebocontrolled trial of carvedilol in patients with congestive heart failure due to ischaemic heart disease. Lancet. 1997;349:375-380. Ra. [pmid: 9033462].
196 Pitt B, Segal R, Martinez F A. for the ELITE Study Investigators, et al. Randomised trial of losartan versus captopril in patients over 65 with heart failure (Evaluation of Losartan in the Elderly Study, ELITE). Lancet. 1997;349:747-752. Ra. [pmid: 9074572].
197 Packer M, O'Connor C M, Ghali J K. for the Prospective Randomized Amlodipine Survival Evaluation Study Group, et al. Effect of amlodipine on morbidity and mortality in severe chronic heart failure. New Engl J Med. 1996;335:1107-1114. Ra. [pmid: 8813041].
198 Cohn J N, Ziesche S, Smith R. for the Vasodilator-Heart Failure Trial, et al. Effect of the calcium antagonist felodipine as supplementary vasodilator therapy in patients with chronic heart failure treated with enalapril: V-HeFT III. Circulation. 1997;96:856-863. Ra. [pmid: 9264493].
199 Veterans Administration Cooperative Study Group on Antihypertensive Agents. Effects of treatment on morbidity in hypertension: results in patients with diastolic blood pressures averaging 115 through 129 mm Hg. JAMA. 1967;202:1028-1034. Ra. [pmid: 4862069].
200 Preston R A, Singer I, Epstein M. Renal parenchymal hypertension: current concepts of pathogenesis and management. Arch Intern Med. 1996;156:602-611. Pr. [pmid: 8629871].
201 Fogo A, Smith M C, Cleveland W, Debruge J, Agodoa L. for the AASK Pilot Investigators. Renal biopsy findings in the African-American Study of Kidney Disease (AASK) [abstract]. J Am Soc Nephrol. 1994;5:560. X.
202 Perry H M Jr, Miller J P, Fornoff J R, et al. Early predictors of 15-year end-stage renal disease in hypertensive patients. Hypertension. 1995;25:587-594. F. [pmid: 7721402].
203 Klag M J, Whelton P K, Randall B L, et al. Blood pressure and end-stage renal disease in men. New Engl J Med. 1996;334:13-18. F. [pmid: 7494564].
204 National High Blood Pressure Education Program Working Group. 1995 update of the working group reports on chronic renal failure and renovascular hypertension. Arch Intern Med. 1996;156:1938-1947. Pr. [pmid: 8823147].
205 Bakris G L, Mangrum A, Copley J B, Vicknair N, Sadler R. Effect of calcium channel or β-blockade on the progression of diabetic nephropathy in African Americans. Hypertension. 1997;29:744-750. Pr. [pmid: 9052890].
206 Lewis E J, Hunsicker L G, Bain R P, Rohde R D. for the Collaborative Study Group. The effect of angiotensin-converting-enzyme inhibition on diabetic nephropathy. N Engl J Med. 1993;329:1456-1462. Ra. [pmid: 8413456].
207 Klahr S, Levey A S, Beck G J. for the Modification of Diet in Renal Disease Study Group, et al. The effects of dietary protein restriction and blood-pressure control on the progression of chronic renal disease. N Engl J Med. 1994;330:877-884. Ra. [pmid: 8114857].
208 Maschio G, Alberti D, Janin G. for the Angiotensin-Converting-Enzyme Inhibition in Progressive Renal Insufficiency Study Group, et al. Effect of the angiotensin-converting-enzyme inhibitor benazepril on the progression of chronic renal insufficiency. N Engl J Med. 1996;334:939-945. Ra. [pmid: 8596594].
209 Giatras I, Lau J, Levey A S. for the Angiotensin-Converting Enzyme Inhibition and Progressive Renal Disease Study Group. Effect of angiotensin-converting enzyme inhibitors on the progression of nondiabetic renal disease: a meta-analysis of randomized trials. Ann Intern Med. 1997;127:337-345. M. [pmid: 9273824].
210 Textor S C. Renal failure related to angiotensin-converting enzyme inhibitors. Semin Nephrol. 1997;17:67-76. Pr. [pmid: 9000551].
211 Appel R G, Bleyer A J, Reavis S, Hansen K J. Renovascular disease in older patients beginning renal replacement therapy. Kidney Int. 1995;48:171-176. F. [pmid: 7564074].
212 Vidt D G. Cholesterol emboli: a common cause of renal failure. Annu Rev Med. 1997;48:375-385. Pr. [pmid: 9046969].
213 Bonelli F S, McKusick M A, Textor S C, et al. Renal artery angioplasty: technical results and clinical outcome in 320 patients. Mayo Clin Proc. 1995;70:1041-1052. Re. [pmid: 7475333].
214 Sos T A. Angioplasty for the treatment of azotemia and renovascular hypertension in atherosclerotic renal artery disease. Circulation. 1991;83(suppl I):I-162-I-166. Pr. [pmid: 1825044].
215 Harden P N, MacLeod M J, Rodger R S C, et al. Effect of renal-artery stenting on progression of renovascular renal failure. Lancet. 1997;349:1133-1136. C. [pmid: 9113012].
216 Zierler R E, Bergelin R O, Davidson R C, Cantwell-Gab K, Polissar N L, Strandness D E Jr. A prospective study of disease progression in patients with atherosclerotic renal artery stenosis. Am J Hypertens. 1996;9:1055-1061. F. [pmid: 8931829].
217 American Diabetes Association. American Diabetes Association: clinical practice recommendations. Diabetes Care. 1997;20(suppl):S1-S70. Pr. [pmid: 9028710].
218 National High Blood Pressure Education Program Working Group. National High Blood Pressure Education Program working group report on hypertension in diabetes. Hypertension. 1994;23:145-158. Pr. [pmid: 8307622].
219 Curb J D, Pressel S L, Cutler J A. for the Systolic Hypertension in the Elderly Program Cooperative Research Group, et al. Effect of diuretic-based antihypertensive treatment on cardiovascular disease risk in older diabetic patients with isolated systolic hypertension. JAMA. 1996;276:1886-1892. Ra. [pmid: 8968014].
220 Shorr R I, Ray W A, Daugherty J R, Griffin M R. Antihypertensives and the risk of serious hypoglycemia in older persons using insulin or sulfonylureas. JAMA. 1997;278:40-43. Re. [pmid: 9207336].
221 Ravid M, Lang R, Rachmani R, Lishner M. Long-term renoprotective effect of angiotensin-converting enzyme inhibition in non-insulin-dependent diabetes mellitus: a 7-year follow-up study. Arch Intern Med. 1996;156:286-289. Ra. [pmid: 8572838].
222 Kasiske B L, Kalil R S N, Ma J Z, Liao M, Keane W F. Effect of antihypertensive therapy on the kidney in patients with diabetes: A meta-regression analysis. Ann Intern Med. 1993;118:129-138. M. [pmid: 8416309].
223 Bakris G L, Copley J B, Vicknair N, Sadler R, Leurgans S. Calcium channel blockers versus other antihypertensive therapies on progression of NIDDM associated nephropathy. Kidney Int. 1996;50:1641-1650. Ra. [pmid: 8914031].
224 Velussi M, Brocco E, Frigato F, et al. Effects of cilazapril and amlodipine on kidney function in hypertensive NIDDM patients. Diabetes. 1996;45:216-222. Ra. [pmid: 8549868].
225 Reaven G M, Lithell H, Landsberg L. Hypertension and associated metabolic abnormalities—the role of insulin resistance and the sympathoadrenal system. New Engl J Med. 1996;334:374-381. Pr. [pmid: 8538710].
226 Kotchen T A. Attenuation of hypertension by insulin-sensitizing agents. Hypertension. 1996;28:219-223. Pr. [pmid: 8707385].
227 Working Group on Management of Patients With Hypertension and High Blood Cholesterol. National education programs working group report on the management of patients with hypertension and high blood cholesterol. Ann Intern Med. 1991;114:224-237. Pr. [pmid: 1984747].
228 Kasiske B L, Ma J Z, Kalil R S N, Louis T A. Effects of antihypertensive therapy on serum lipids. Ann Intern Med. 1995;122:133-141. Pr. [pmid: 7992988].
229 Stamler J, Briefel R R, Milas C, Grandits G A, Caggiula A W. Relation of changes in dietary lipids and weight, trial years 1–6, to changes in the special intervention and usual care groups in the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65(suppl):272S-288S. F. [pmid: 8988942].
230 Grimm R H Jr, Flack J M, Grandits G A. for the Treatment of Mild Hypertension Study (TOMHS) Research Group, et al. Long-term effects on plasma lipids of diet and drugs to treat hypertension. JAMA. 1996;275:1549-1556. Ra, F. [pmid: 8622245].
231 Frost P H, Davis B R, Burlando A J. for the Systolic Hypertension in the Elderly Research Group, et al. Serum lipids and incidence of coronary heart disease: findings from the Systolic Hypertension in the Elderly Program (SHEP). Circulation. 1996;94:2381-2388. F. [pmid: 8921777].
232 Curb J D, Maxwell M H, Schneider K A, Taylor J O, Shulman N B. Adverse effects of antihypertensive medications in the Hypertension Detection and Follow-up Program. Prog Cardiovasc Dis. 1986;29(suppl 1):73-88. F. [pmid: 3538181].
233 Lind L, Pollare T, Berne C, Lithell H. Long-term metabolic effects of antihypertensive drugs. Am Heart J. 1994;128:1177-1183. F. [pmid: 7985599].
234 Yusuf S, Peto R, Lewis J, Collins R, Sleight P. Beta blockade during and after myocardial infarction: an overview of the randomized trials. Prog Cardiovasc Dis. 1985;27:335-371. M. [pmid: 2858114].
235 Sacks F M, Pfeffer M A, Moye L A. for the Cholesterol and Recurrent Events Trial Investigators, et al. The effect of pravastatin on coronary events after myocardial infarction in patients with average cholesterol levels. N Engl J Med. 1996;335:1001-1009. Ra. [pmid: 8801446].
236 Shepherd J, Cobbe S M, Ford I. for the West of Scotland Coronary Prevention Study Group, et al. Pre-vention of coronary heart disease with pravastatin in men with hypercholesterolemia. N Engl J Med. 1995;333:1301-1307. Ra. [pmid: 7566020].
237 Scandinavian Simvastatin Survival Study Group. Randomised trial of cholesterol lowering in 4444 patients with coronary heart disease: the Scandina-vian Simvastatin Survival Study (4S). Lancet. 1994;344:1383-1389. Ra. [pmid: 7968073].
238 Hebert P R, Gaziano J M, Chan K S, Hennekens C H. Cholesterol lowering with statin drugs, risk of stroke, and total mortality. An overview of randomized trials. JAMA. 1997;278:313-321. M. [pmid: 9228438].
239 National Cholesterol Education Program. Second report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel II). Circulation. 1994;89:1329-1445. Pr.
240 Hung J, Whitford E G, Parsons R W, Hillman D R. Association of sleep apnoea with myocardial infarction in men. Lancet. 1990;336:261-264. Re. [pmid: 1973968].
241 He J, Kryger M H, Zorick F J, Conway W, Roth T. Mortality and apnea index in obstructive sleep apnea: experience in 385 male patients. Chest. 1988;94:9-14. F. [pmid: 3289839].
242 Sanders B P, Portman R J, Ramey R A, Hill M, Strunk R C. Hypertension during reduction of long-term steroid therapy in young subjects with asthma. J Allergy Clin Immunol. 1992;89:816-821. F. [pmid: 1560165].
243 Langford H G, Blaufox M D, Borhani N O. on behalf of the Hypertension Detection and Follow-up Cooperative Group, et al. Is thiazide-produced uric acid elevation harmful? Analysis of data from the Hypertension Detection and Follow-up Program. Arch Intern Med. 1987;147:645-649. F. [pmid: 3827451].
244 Eagle K A, Brundage B H, Chaitman B R, et al. Guidelines for perioperative cardiovascular evaluation for noncardiac surgery: report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Perioperative Cardiovascular Evaluation for Noncardiac Surgery). J Am Coll Cardiol. 1996;27:910-948. Pr. [pmid: 8613622].
245 Riles T S, Fisher F S, Schaefer S, Pasternack P F, Baumann F G. Plasma catecholamine concentrations during abdominal aortic aneurysm surgery: the link to perioperative myocardial ischemia. Ann Vasc Surg. 1993;7:213-219. [pmid: 8318383].
246 Mangano D T, Layug E L, Wallace A, Tateo I. for the Multicenter Study of Perioperative Ischemia Research Group, et al. Effect of atenolol on mortality and cardiovascular morbidity after noncardiac surgery. N Engl J Med. 1996;335:1713-1720. Ra. [pmid: 8929262].
247 Pahor M, Guralnik J M, Furberg C D, Carbonin P, Havlik R J. Risk of gastrointestinal haemorrhage with calcium antagonists in hypertensive persons over 67 years old. Lancet. 1996;347:1061-1065. F. [pmid: 8602055].
248 Zuccalà G, Pahor M, Landi F, et al. Use of calcium antagonists and need for perioperative transfusion in older patients with hip fracture: observational study. BMJ. 1997;314:643-644. C. [pmid: 9066477].
249 Brecklin C, Gopaniuk A, Kravetz T, et al. Chronic cocaine abuse causes acute but not chronic hypertension [abstract]. J Am Soc Nephrol. 1996;7:1547.
250 Herzlich B C, Arsura E L, Pagala M, Grob D. Rhabdomyolysis related to cocaine abuse. Ann Intern Med. 1988;109:335-336. [pmid: 3395041].
251 Hollander J E. The management of cocaine-associated myocardial ischemia. N Engl J Med. 1995;333:1267-1272. X. [pmid: 7566005].
252 Lange R A, Cigarroa R G, Flores E D, et al. Potentiation of cocaine-induced coronary vasoconstriction by beta-adrenergic blockade. Ann Intern Med. 1990;112:897-903. Ra. [pmid: 1971166].
253 Textor S C, Taler S J, Canzanello V J, Schwartz L. Cyclosporine, blood pressure and atherosclerosis. Cardiology in Review. 1997;5:141-151. Pr.
254 Grossman E, Messerli F H. High blood pressure: a side effect of drugs, poisons, and food. Arch Intern Med. 1995;155:450-460. [pmid: 7864701].