# Acknowledgments

## Chair

Sheldon G. Sheps, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN)

## Executive Committee

Henry R. Black, MD, Chair of Chapter 1 (Rush-Presbyterian-St. Luke’s Medical Center, Chicago, IL);

Jerome D. Cohen, MD, Chair of Chapter 2 (St. Louis University Health Sciences Center, St. Louis, MO);

Norman M. Kaplan, MD, Chair of Chapter 3 (University of Texas Southwestern Medical School, Dallas, TX);

Keith C. Ferdinand, MD, Chair of Chapter 4 (Heartbeats Life Center, New Orleans, LA);

Aram V. Chobanian, MD (Boston University, Boston, MA);

Harriet P. Dustan, MD (University of Vermont College of Medicine, Burlington, VT);

Ray W. Gifford, Jr., MD (Cleveland Clinic Foundation, Cleveland, OH);

Marvin Moser, MD (Yale University School of Medicine, New Haven, CT);

Sheldon G. Sheps, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN).

## Contributors

Lawrence Agodoa, MD (National Institute of Diabetes and Digestive and Kidney Diseases, Bethesda, MD);

Phyllis A. August, MD (New York Hospital, New York, NY);

George L. Bakris, MD (Rush-Presbyterian-St. Luke’s Medical Center, Chicago, IL);

Vicki Burt, RN, ScM (National Center for Health Statistics, Hyattsville, MD);

William Busse, MD (University of Wisconsin, Madison, WI);

Barry L. Carter, PharmD (University of Colorado, Denver, CO);

Francis D. Chesley, MD (Agency for Health Care Policy and Research, Rockville, MD);

James Cleeman, MD (National Heart, Lung, and Blood Institute, Bethesda, MD);

Jay N. Cohn, MD (University of Minnesota Medical School, Minneapolis, MN);

Louis L. Cregler, MD (City University of New York Medical School, New York, NY);

Carlos Crespo, DrPH, MS (American University, Washington, DC);

William C. Cushman, MD (University of Tennessee College of Medicine, Memphis, TN);

Jeffrey Cutler, MD, MPH (National Heart, Lung, and Blood Institute, Bethesda, MD);

Mark D. Darrow, MD (East Carolina University School of Medicine, Greenville, NC);

Vincent L. DeQuattro, MD (University of Southern California Medical Center, Los Angeles, CA);

Richard B. Devereux, MD (Cornell University Medical Center, New York, NY);

Lance D. Dworkin, MD (Rhode Island Hospital, Providence, RI);

William J. Elliott, MD, PhD (Rush-Presbyterian-St. Luke’s Medical Center, Chicago, IL);

Murray Epstein, MD (University of Miami School of Medicine, Miami, FL);

Bonita Falkner, MD (Allegheny University of the Health Sciences, Philadelphia, PA);

Carlos M. Ferrario, MD (Bowman Gray School of Medicine, Winston-Salem, NC);

John M. Flack, MD, MPH (Bowman Gray School of Medicine of Wake Forest University, Winston-Salem, NC);

William Frishman, MD (Albert Einstein College of Medicine/Montefiore Medical Center, Bronx, NY);

Edward D. Frohlich, MD (Alton Ochsner Medical Foundation, New Orleans, LA);

Lee A. Green, MD, MPH (University of Michigan, Ann Arbor, MI);

Richard H. Grimm, Jr., MD, PhD (University of Minnesota Medical School, Minneapolis, MN);

James M. Hagberg, PhD (University of Maryland, College Park, MD);

W. Dallas Hall, MD (Emory University, Atlanta, GA);

Joel Handler, MD (Kaiser Permanente, Anaheim, CA);

Stephen Havas, MD, MPH, MS (University of Maryland School of Medicine, Baltimore, MD);

Martha N. Hill, PhD, MSN (Johns Hopkins University, Baltimore, MD);

Michael J. Horan, MD, ScM (National Heart, Lung, and Blood Institute, Bethesda, MD);

Willa A. Hsueh, MD (University of Southern California Medical Center, Los Angeles, CA);

Barry N. Hyman, MD (Baylor College of Medicine, Houston, TX);

Joseph L. Izzo, Jr., MD (State University of New York, Buffalo, NY);

Kenneth Jamerson, MD (University of Michigan Medical Center, Ann Arbor, MI);

James P. Kiley, PhD (National Heart, Lung, and Blood Institute, Bethesda, MD);

Mehendr S. Kochar, MD, MS (Medical College of Wisconsin, Milwaukee, WI);

Kathryn M. Kolasa, PhD, RD, LDN (East Carolina University School of Medicine, Greenville, NC);

Lawrence R. Krakoff, MD (Englewood Hospital, Englewood, NJ);

Daniel Levy, MD (Framingham Heart Study, National Heart, Lung, and Blood Institute, Framingham, MA);

Marshall D. Lindheimer, MD (University of Chicago Hospitals, Chicago, IL);

Russell V. Luepker, MD (University of Minnesota, Minneapolis, MN);

Mary E. Leavell Malone, MA, MSN (Jefferson Community College, Louisville, KY);

Barry Massie, MD (University of California, San Francisco, CA);

Barry J. Materson, MD, MBA (University of Miami, Miami, FL);

Jay Merchant, MHA (Health Care Financing Administration, Washington, DC);

Franz H. Messerli, MD (Ochsner Clinic and Alton Ochsner Medical Foundation, New Orleans, LA);

Nancy Houston Miller, BSN (Stanford Cardiac Rehabilitation Program, Palo Alto, CA);

Michael A. Moore, MD (Bowman Gray School of Medicine, Winston-Salem, NC);

Lisa Mustone-Alexander, MPH, PA (George Washington University School of Medicine and Health Sciences, Washington, DC);

Suzanne Oparil, MD (University of Alabama at Birmingham, Birmingham, AL);

Vasilios Papademetriou, MD (Veterans Affairs Medical Center, Washington, DC);

H. Mitchell Perry, Jr., MD (Washington University School of Medicine, St. Louis, MO);

Thomas G. Pickering, MD, DPhil (Cornell University Medical Center, New York, NY);

J. Howard Pratt, MD (Indiana University School of Medicine, Indianapolis, IN);

C. Venkata S. Ram, MD (University of Texas Southwestern Medical Center, Dallas, TX);

Otelio S. Randall, MD (Howard University Hospital, Washington, DC);

James W. Reed, MD (Morehouse School of Medicine, Atlanta, GA);

Raymond W. Roberts, PharmD (Vencor, Louisville, KY);

Edward J. Roccella, PhD, MPH (National Heart, Lung, and Blood Institute, Bethesda, MD);

Susan D. Rogus, RN, MS (National Heart, Lung, and Blood Institute, Bethesda, MD);

Elijah Saunders, MD (University of Maryland, Baltimore, MD);

Eleanor Schron, RN, MSN (National Heart, Lung, and Blood Institute, Bethesda, MD);

Gary Schwartz, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN);

Baha M. Sibai, MD (University of Tennessee College of Medicine, Memphis, TN);

David Snyder, RPh, DDS (Health Resources and Services Administration, Rockville, MD);

James R. Sowers, MD (Wayne State University, Detroit, MI);

Jeremiah Stamler, MD (Northwestern University Medical School, Chicago, IL);

Robert Temple, MD (Food and Drug Administration, Rockville, MD);

Steve Textor, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN);

Thomas Thom, BA (National Heart, Lung, and Blood Institute, Bethesda, MD);

Donald G. Vidt, MD (Cleveland Clinic Foundation, Cleveland, OH);

Michael Weber, MD (Brookdale Hospital, Brooklyn, NY);

Myron H. Weinberger, MD (Indiana University School of Medicine, Indianapolis, IN);

Richard Weinshilboum, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN);

Paul K. Whelton, MD, MSc (Tulane University School of Public Health and Tropical Medicine, New Orleans, LA);

Jack P. Whisnant, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN);

David O. Wiebers, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN);

Mary C. Winston, EdD, RD (American Heart Association, Dallas, TX);

Jackson T. Wright, Jr., MD, PhD (Case Western Reserve University, Cleveland, OH).

## National High Blood Pressure Education Program Coordinating Committee

Claude Lenfant, MD, Chair (National Heart, Lung, and Blood Institute);

Henry R. Black, MD (American Heart Association);

Vicki Burt, RN, ScM (National Center for Health Statistics, Centers for Disease Control and Prevention);

Barry L. Carter, PharmD (American Society of Health-System Pharmacists);

Linda Casser, OD (American Optometric Association);

Francis D. Chesley, MD (Agency for Health Care Policy and Research);

Jerome D. Cohen, MD (American College of Physicians);

Pamela J. Colman, DPM (American Podiatric Medical Association);

Thelma Edwards, RN (National Stroke Association);

Murray Epstein, MD (National Kidney Foundation);

Donna M. Feeley, MPH (American Red Cross);

Keith Copelin Ferdinand, MD (National Heart, Lung, and Blood Institute Ad Hoc Committee on Minority Populations);

Edward D. Frohlich, MD (American College of Cardiology);

Jerzy Gajewski, MD, PhD (American Academy of Insurance Medicine);

Ray W. Gifford, Jr., MD (American Medical Association);

Lee A. Green, MD, MPH (American Academy of Family Physicians);

Stephen Havas, MD, MPH, MS (American Public Health Association);

Caroline Haynes, RN, MPH, COHN (American Association of Occupational Health Nurses);

Barry N. Hyman, MD (American Academy of Ophthalmology);

Joseph L. Izzo, Jr., MD (Council on Geriatric Cardiology);

Norman M. Kaplan, MD (American Society of Hypertension);

Kathryn M. Kolasa, PhD, RD, LDN (Society for Nutrition Education);

David Levine, MD, ScD, MPH (American College of Preventive Medicine);

Mary E. Leavell Malone, MA, MSN (National Black Nurses’ Association);

William Manger, MD, PhD (National Hypertension Association);

Edwin C. Marshall, OD, MPH (National Optometric Association);

Jay Merchant, MHA (Health Care Financing Administration);

Nancy Houston Miller, BSN (American Nurses’ Association);

Marvin Moser, MD (National High Blood Pressure Education Program);

Lisa Mustone-Alexander, MPH, PA (American Academy of Physician Assistants);

William A. Nickey, DO (American Osteopathic Association);

H. Mitchell Perry, Jr., MD (U.S. Department of Veterans Affairs);

Otelio S. Randall, MD (National Medical Association);

James W. Reed, MD (International Society on Hypertension in Blacks);

Raymond W. Roberts, PharmD (American Pharmaceutical Association);

Brodie G. Secrest, Jr., DDS (American Dental Association);

Sheldon G. Sheps, MD (American College of Chest Physicians);

Elizabeth H. Singer, MS (National Institute of Diabetes and Digestive and Kidney Diseases, Bethesda, MD);

David Snyder, RPh, DDS (Health Resources and Services Administration);

James R. Sowers, MD (American Diabetes Association);

Jack P. Whisnant, MD (American Academy of Neurology);

Gerald J. Wilson, MA, MBA (Citizens for Public Action on High Blood Pressure and Cholesterol);

Mary C. Winston, EdD, RD (American Dietetic Association);

Jackson T. Wright, Jr., MD, PhD (Association of Black Cardiologists);

Joyce M. Young, MD (American College of Occupational and Environmental Medicine).

## Reviewers

John W. Bachman, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN);

Vito M. Campese, MD (University of Southern California Medical Center, Los Angeles, CA);

Albert A. Carr, MD (Circulatory Disease Center— Augusta Preventive Cardiology, Augusta, Georgia);

Mary Hand, MSPH, RN (National Heart, Lung, and Blood Institute, Bethesda, MD);

David C. Holden, MD (Family Practice, Peoria, IL);

Michael J. Jamieson, MD (University of Texas Health Sciences Center, San Antonio, TX);

Stevo Julius, MD (University of Michigan Medical Center, Ann Arbor, MI);

George A. Mensah, MD (Medical College of Georgia, Augusta, GA);

L. Michael Prisant, MD (Medical College of Georgia, Augusta, GA);

Jay M. Sullivan, MD (University of Tennessee, Memphis, TN);

Daniel J. Wilson, MD (Mayo Clinic and Mayo Foundation and Mayo Medical School, Rochester, MN).

## Staff

Edward J. Roccella, PhD, MPH (National Heart, Lung, and Blood Institute, Bethesda, MD);

Gregory Morosco, PhD, MPH (National Heart, Lung, and Blood Institute, Bethesda, MD);

Darrell E. Anderson, MS (R.O.W. Sciences, Inc., Rockville, MD);

Debra Waugh, BA (R.O.W. Sciences, Inc., Rockville, MD).