# Special Populations and Situations

## Hypertension in Racial and Ethnic Minorities

The United States is a diverse nation composed of individuals from many cultures. The 1990 census reported that the U.S. population was 0.8 percent American Indians, Aleuts, and Inuits; 2.9 percent Asians and Pacific Islanders; 9.0 percent persons of Hispanic origin; 12.1 percent African Americans; and 80.3 percent white.^146^ (These self-reported categories are not mutually exclusive; thus, the total is greater than 100 percent.) In the past decade, the country has experienced a marked increase in minority populations and the number of immigrants. This trend is expected to continue.

As immigrant populations acculturate, their risk for cardiovascular disease changes.^147F^ The prevalence of hypertension differs among racial and ethnic groups compared with the general population.^148Pr^ For example, American Indians have the same prevalence as, or a higher prevalence than, the general population; among His-panics, blood pressure is generally the same as or lower than that of non-Hispanic whites, despite a high prevalence of obesity and type 2 diabetes mellitus. It also appears that South Asians are more responsive to various antihypertensive medications than whites.^149C,^ ^150X^ Evidence shows that hypertension awareness, treatment, and control in some groups, especially those with generally lower socioeconomic status, require more focused hypertension education and intervention programs.^148Pr,^ ^151X,^ ^152X,^ ^153X^

The prevalence of hypertension in African Americans is among the highest in the world. Compared with whites, hypertension develops earlier in life and average blood pressures are much higher in African Americans. African Americans have higher rates of stage 3 hypertension than whites, causing a greater burden of hypertension complications.^14Pr,^ ^24X^ This earlier onset, higher prevalence, and greater rate of stage 3 hypertension in African Americans is accompanied by an 80-percent higher stroke mortality rate, a 50-percent higher heart disease mortality rate, and a 320-percent greater rate of hypertension-related end-stage renal disease than seen in the general population.^154X,^ ^155F^

Available evidence indicates that, compared with whites, African Americans receiving adequate treatment will achieve similar overall declines in blood pressure and may experience a lower incidence of cardiovascular disease.^156Ra,^ ^157F^ However, African Americans often do not receive treatment until blood pressure has been elevated a long time and target organ damage is present. This also may account for the higher incidence of hypertension-related morbidity and mortality in the African American population, including end-stage renal disease.^155F^

Because of the high prevalence of cardiovascular risk factors in African Americans—such as obesity, cigarette smoking, and type 2 diabetes—as well as increased responsiveness to reduced salt intake, lifestyle modifications are particularly important.

In African Americans, as well as in whites, diuretics have been proven in controlled trials to reduce hypertensive morbidity and mortality; thus, diuretics should be the agent of first choice in the absence of conditions that prohibit their use. Calcium antagonists and alpha-betablockers are also effective in lowering blood pressure.^129Ra,^ ^158Ra^ Monotherapy with beta-blockers or ACE inhibitors is less effective, but the addition of diuretics markedly improves response. However, these agents are indicated regardless of ethnicity when patients have other specific indications (e.g., beta-blockers for angina or post-myocardial infarction, ACE inhibitors for diabetic nephropathy or left ventricular systolic dysfunction).^159Ra^

Because of their greater prevalence of stage 3 hypertension, many African American patients require multidrug therapy. Every effort should be made to achieve a goal blood pressure of below 140/90 mm Hg. In patients with renal insufficiency, recent data suggest that reducing blood pressure to an even lower level may be beneficial (see discussion of renal disease in this chapter).

## Hypertension in Children and Adolescents

The fifth Korotkoff sound is now used to define DBP for all ages. Definitions of hypertension take into account age and height by sex. Blood pressure at the 95th percentile or greater is considered elevated (Table 14). Clinicians should be alert to the possibility of identifiable causes of hypertension in younger children. Lifestyle interventions should be recommended, with pharmacologic therapy instituted for higher levels of blood pressure or if there is insufficient response to lifestyle modifications. Although the recommendations for choice of drugs are similar in children and adults, dosages of antihypertensive medication should be smaller and adjusted very carefully for children. ACE inhibitors and angiotensin II receptor blockers should not be used in pregnant or sexually active girls.

Table 14 95th Percentile of Blood Pressure by Selected Ages in Girls and Boys, by the 50th and 75th Height Percentiles*

| Girls' SBP/DBP | | Boys' SBP/DBP
Age (Years) | 50th Percentile for Height | 75th Percentile for Height | 50th Percentile for Height | 75th Percentile for Height
1 | 104/58 | 105/59 | 102/57 | 104/58
6 | 111/73 | 112/73 | 114/74 | 115/75
12 | 123/80 | 124/81 | 123/81 | 125/82
17 | 129/84 | 130/85 | 136/87 | 138/88

* Adapted from the report by the NHBPEP Working Group on Hypertension Control in Children and Adolescents.^160^ SBP indicates systolic blood pressure; DBP, diastolic blood pressure.

Uncomplicated elevated blood pressure alone should not be a reason to restrict asymptomatic children from participating in physical activities, particularly because exercise may lower blood pressure and prevent hypertension. Use of anabolic steroid hormones for the purpose of bodybuilding should be strongly discouraged. Efforts should be made to discover other risk factors (e.g., smoking) in children, and interventions should be made if they are present. Detailed recommendations regarding hypertension in children and adolescents can be found in the 1996 report by the NHBPEP Working Group on Hypertension Control in Children and Adolescents.^160Pr^

## Hypertension in Women

Large, long-term clinical trials of antihypertensive treatment have included both men and women and have not demonstrated clinically significant sex differences in blood pressure response and outcomes.^128M^ Recent trials of older persons support a similar approach to hypertension management in men and women.^26Pr^

### Hypertension Associated With Oral Contraceptives

Women taking oral contraceptives experience a small but detectable increase in both SBP and DBP, usually within the normal range. Hypertension has been reported to be two to three times more common in women taking oral contraceptives, especially in obese and older women, than in those not taking oral contraceptives.^161Pr^ Women age 35 and older who smoke cigarettes should be strongly counseled to quit; if they continue to smoke, they should be discouraged from using oral contraceptives.

If hypertension develops in women taking oral contraceptives, it is advisable to stop their use. Blood pressure will normalize in most cases within a few months. If high blood pressure persists, if the risks for pregnancy are considered to be greater than the risks for hypertension, and if other contraceptive methods are not suitable, then oral contraceptives may have to be continued and therapy for hypertension begun. A prudent approach to the use of oral contraceptives is to prescribe no more than a 6-month supply at a time in order to measure blood pressure on a semiannual basis.

### Hypertension in Pregnancy

Chronic hypertension is high blood pressure that is present and observable before pregnancy or that is diagnosed before the 20th week of gestation. The goal of treatment for women with chronic hypertension in pregnancy is to minimize the short-term risks of elevated blood pressure to the mother while avoiding therapy that compromises the well-being of the fetus. If taken before pregnancy, diuretics and most other antihypertensive drugs, except ACE inhibitors and angiotensin II receptor blockers, may be continued. Methyldopa has been evaluated most extensively and is therefore recommended for women whose hypertension is first diagnosed during pregnancy. Beta-blockers compare favorably with methyldopa with respect to efficacy and are considered safe in the latter part of pregnancy; however, their use in early pregnancy may be associated with growth retardation of the fetus (Table 15). ACE inhibitors and angiotensin II receptor blockers should be avoided because serious neonatal problems, including renal failure and death, have been reported when mothers have taken these agents during the last two trimesters of pregnancy.^162Pr^

Antihypertensive Drugs Used in Pregnancy*

The report of the NHBPEP Working Group on High Blood Pressure in Pregnancy^165^ permits continuation of drug therapy in women with chronic hypertension (except for ACE inhibitors). In addition, angiotensin II receptor blockers should not be used during pregnancy. In women with chronic hypertension with diastolic levels of 100 mm Hg or greater (lower when end organ damage or underlying renal disease is present) and in women with acute hypertension when levels are 105 mm Hg or greater, the following agents are suggested.
Suggested Drug | Comments
Central alpha-agonists | Methyldopa (C) is the drug of choice recommended by the NHBPEP Working Group.^165^
Beta-blockers | Atenolol (C) and metoprolol (C) appear to be safe and effective in late pregnancy. Labetalol (C) also appears to be effective (alpha- and beta-blockers).
Calcium antagonists | Potential synergism with magnesium sulfate may lead to precipitous hypotension. (C)
ACE inhibitors, angiotensin II receptor blockers | Fetal abnormalities, including death, can be caused, and these drugs should not be used in pregnancy. (D)
Diuretics | Diuretics (C) are recommended for chronic hypertension if prescribed before gestation or if patients appear to be salt-sensitive. They are not recommended in preeclampsia.
Direct vasodilators | Hydralazine (C) is the parenteral drug of choice based on its long history of safety and efficacy. (C)

* Adapted from Sibai^162^ and Lindheimer.^163^ There are several other antihypertensive drugs for which there are very limited data. The U.S. Food and Drug Administration classifies pregnancy risk as follows: C, adverse effects in animals; no controlled trials in humans; use if risk appears justified; D, positive evidence of fetal risk. ACE indicates angiotensin-converting enzyme.

Preeclampsia. Preeclampsia, a pregnancyspecific condition, is increased blood pressure accompanied by proteinuria, edema, or both and at times by abnormalities of coagulation and renal and liver function that may progress rapidly to a convulsive phase, eclampsia. Preeclampsia occurs primarily during first pregnancies and after the 20th week of gestation. It may be superimposed on preexisting chronic hypertension. Large trials have not confirmed the benefit of prophylactic low-dose aspirin or supplemental calcium to prevent preeclampsia.^163Pr,^ ^164Pr^ A detailed summary of hypertension in pregnancy was published in a report by the NHBPEP Working Group on High Blood Pressure in Pregnancy.^165Pr^ More recent reviews have been published.^162Pr,^ ^163Pr^

### Hormone Replacement Therapy and Blood Pressure Response

The presence of hypertension is not a contraindication to postmenopausal estrogen replacement therapy. A recent study indicated that blood pressure does not increase significantly with hormone replacement therapy in most women with and without hypertension and that hormone replacement therapy has a beneficial effect on overall cardiovascular risk factor profiles.^166Ra^ However, a few women may experience a rise in blood pressure attributable to estrogen therapy. Therefore, it is recommended that all women treated with hormone replacement therapy have their blood pressure monitored more frequently after such therapy is instituted. The effect of transdermal estrogen and progestogen on blood pressure has not been established.

## Hypertension in Older Persons

Hypertension is extremely common in older Americans. Among Americans age 60 and older examined in the NHANES III, elevated blood pressure was found in 60 percent of non-Hispanic whites, 71 percent of non-Hispanic African Americans, and 61 percent of Mexican Americans.^24X^ Especially among older persons, SBP is a better predictor of events (coronary heart disease, cardiovascular disease, heart failure, stroke, end-stage renal disease, and all-cause mortality) than is DBP. ^26Pr^ Recently, it has become clear that an elevated pulse pressure (SBP minus DBP), which indicates reduced vascular compliance in large arteries, may be an even better marker of increased cardiovascular risk than either SBP or DBP alone.^139F^ This is particularly relevant to older individuals who frequently have an isolated elevation of SBP (140 mm Hg or greater with a DBP below 90 mm Hg) (Table 2). Those with stage 1 isolated systolic hypertension are at significantly increased cardiovascular risk, but the benefits of treatment in those individuals have not yet been demonstrated in a controlled trial.^167F^

Primary hypertension is by far the most common form of hypertension in older persons. However, clinicians must recognize that certain identifiable causes of hypertension (e.g., atherosclerotic renovascular hypertension, primary aldosteronism) may occur more frequently in older persons, especially in those whose hypertension first presented after age 60 or is resistant to treatment.^145Pr^

Blood pressure must be measured in older persons with special care because some older persons have pseudohypertension (falsely high sphygmomanometer readings) due to excessive vascular stiffness.^168^ In addition, more older persons with hypertension, especially women, may have “white-coat hypertension” and excessive variability in SBP.^169X^ In the absence of target organ damage, clinicians should consider pseudohypertension or “white-coat hypertension” and should obtain readings outside the office (see chapter 2). In addition, older patients are more likely than younger patients to exhibit an orthostatic fall in blood pressure and hypotension; thus, in older patients, blood pressure should always be measured in the standing as well as seated or supine positions.^170X^

Treatment of hypertension in older persons has demonstrated major benefits (Figure 7). Large trials of patients older than age 60 have shown that antihypertensive drug therapy reduces stroke, CHD, cardiovascular disease, heart failure, and mortality.^140Ra,^ ^171Ra,^ ^172Ra,^ ^173Ra,^ ^174Ra^

Hypertension therapy in older persons, as in younger persons, should begin with lifestyle modifications.^26Pr^ Older patients will respond to modest salt reduction and weight loss.^80Ra^ If goal blood pressure is not achieved, then pharmacologic treatment is indicated. The starting dose in older patients should be about half of that used in younger patients. Thiazide diuretics or beta-blockers in combination with thiazide diuretics are recommended because they are effective in reducing mortality and morbidity in older persons with hypertension as shown in multiple randomized controlled trials.^120M,^ ^171Ra^ When compared to each other, diuretics (hydrochlorothiazide with amiloride hydrochloride) are superior to the beta-blocker atenolol.^172Ra^ In older patients with isolated systolic hypertension, diuretics are preferred because they have significantly reduced multiple endpoint events.^171Ra^ In addition, an RCT in such patients taking the dihydropyridine nitrendipine showed a 42-percent reduction in fatal and nonfatal stroke over an average 2-year interval.^140Ra^ The concomitant reductions in coronary events and heart failure did not reach statistical significance although a favorable trend was reported and all cardiovascular disease mortality was significantly reduced. Because nitrendipine is not available in the United States, other long-acting dihydropyridine calcium antagonists are considered to be appropriate alternatives in these patients.

The goal of treatment in older patients should be the same as in younger patients (to below 140/90 mm Hg if at all possible), although an interim goal of SBP below 160 mm Hg may be necessary in those patients with marked systolic hypertension.^26Pr^ Any reduction in blood pressure appears to confer benefit—the closer to normal, the greater the benefit. Drugs that exaggerate postural changes in blood pressure (peripheral adrenergic blockers, alpha-blockers, and high-dose diuretics) or drugs that can cause cognitive dysfunction (central alpha_2_-agonists) should be used with caution. Additional recommendations about hypertension in older persons can be found in the report by the NHBPEP Working Group on Hypertension in the Elderly.^26Pr^

## Patients with Hypertension and Coexisting Cardiovascular Diseases

### Patients With Cerebrovascular Disease

Clinically evident cerebrovascular disease is an indication for antihypertensive treatment. However, immediately after the occurrence of an ischemic cerebral infarction, it is appropriate to withhold treatment (unless blood pressure is very high) until the situation has been stabilized. Even when treatment has been withheld temporarily, the eventual goal is to reduce blood pressure gradually while avoiding orthostatic hypotension. Patients with acute ischemic stroke who are treated with fibrinolytic agents require careful blood pressure monitoring, especially over the first 24 hours after starting treatment. SBP of 180 mm Hg or greater or DBP of 105 mm Hg or greater may be controlled with intravenous agents with careful monitoring for worsening of neurological status.^175C^

### Patients With Coronary Artery Disease

Patients with coronary artery disease and hypertension are at particularly high risk for cardiovascular morbidity and mortality. The benefits and safety of antihypertensive therapy in such patients are well established.^176Pr,^ ^177Pr^ Excessively rapid lowering of blood pressure, particularly when it causes reflex tachycardia and sympathetic activation, should be avoided. Blood pressure should be lowered to the usual target range (below 140/90 mm Hg), and even lower blood pressure is desirable if angina persists.

Beta-blockers or calcium antagonists may be specifically useful in patients with hypertension and angina pectoris; however, short-acting calcium antagonists should not be used.^125M,^ ^178Re^ ^179Re^ After myocardial infarction, beta-blockers without intrinsic sympathomimetic activity should be given because they reduce the risk for subsequent myocardial infarction or sudden cardiac death. ACE inhibitors are also useful after myocardial infarction, especially with left ventricular systolic dysfunction, to prevent subsequent heart failure and mortality.^176Pr^

If beta-blockers are ineffective or contraindicated, verapamil hydrochloride or diltiazem hydrochloride may be used because they have been shown to reduce cardiac events and mortality modestly in two circumstances: (1) following non-Q-wave myocardial infarction, and (2) after myocardial infarction with preserved left ventricular function (LVH).^119Pr,^ ^180Pr,^ ^181Pr^

Some patients with hypertension, especially when accompanied by severe LVH, may experience angina without evidence of coronary atherosclerosis. This is thought to reflect an imbalance between myocardial oxygen supply and demand, due in part to changes in the coronary microcirculation. Treatment should be directed at blood pressure control, reversal of LVH, and avoidance of tachycardia, which may exacerbate the supply-demand mismatch.

### Patients With Left Ventricular Hypertrophy

Development of LVH permits cardiac adaptation to the increased afterload imposed by elevated arterial pressure. However, LVH is a major independent risk factor for sudden cardiac death, myocardial infarction, stroke, and other cardiovascular morbid and mortal events.^182F,^ ^183F^ Evidence shows that antihypertensive agents (except direct vasodilators such as hydralazine and minoxidil), weight reduction, and decrease of excessive salt intake are capable of reducing increased left ventricular mass and wall thickness.^184Pr^ In one study in men with hypertension, treatment with a diuretic and an ACE inhibitor was better than treatment with other drug classes tested for regressing LVH at 1 year.^185Ra^ Observational data indicate that the regression of electrocardiographic evidence of LVH is associated with a reduction in the risk for cardiovascular events.^186F^ However, no controlled studies demonstrate that such reversal of LVH offers additional benefits beyond that offered by reduction of blood pressure.^187Pr^ The electrocardiogram remains valuable not only for detecting left atrial hypertrophy and LVH but also for identifying evidence of myocardial ischemia and arrhythmia.^188Pr^ Echocardiography is more sensitive and specific for identifying LVH, but it is too expensive for routine use. Limited echocardiography will identify LVH at a cost that may justify its use in some patients (e.g., those with untreated stage 1 hypertension, no cardiovascular risk factors, no evidence of clinical cardiovascular disease, and no target organ damage).^189Pr^

### Patients With Cardiac Failure

In patients with hypertension, structural alterations in the left ventricle (LVH or left ventricular remodeling with dilation) as well as myocardial ischemia from coronary artery atherosclerosis may contribute to the development of heart failure. Some patients with hypertension (current or past) develop heart failure with a normal ejection fraction, implying diastolic dysfunction. Reports from the Framingham Heart Study have demonstrated that hypertension continues to be the major cause of left ventricular failure in the United States.^190Pr^ Control of elevated arterial pressure using lifestyle changes and drug therapy improves myocardial function and prevents and reduces heart failure and cardiovascular mortality.^119Pr^ After myocardial infarction, therapy with ACE inhibitors prevents subsequent heart failure and reduces morbidity and mortality.^191Ra^ In treating heart failure, ACE inhibitors, when used alone or in conjunction with digoxin or diuretics, are effective in reducing morbidity and mortality.^192M^ When ACE inhibitors are contraindicated or not tolerated, the vasodilator combination of hydralazine hydrochloride and isosorbide dinitrate is also effective in these patients.^193Ra^ The alpha-beta-blocker carvedilol added to ACE inhibitors has been shown to be beneficial,^194Ra,^ ^195Ra^ and, in one trial, the angiotensin II receptor blocker losartan potassium was superior to captopril in reducing mortality.^196Ra^ The dihydropyridine calcium antagonists amlodipine besylate and felodipine have been demonstrated to be safe in treating angina and hypertension in patients with advanced left ventricular dysfunction when used in addition to ACE inhibitors, diuretics, or digoxin;^197Ra,^ ^198Ra^ other calcium antagonists are not recommended in these patients.

### Patients With Peripheral Arterial Disease

Hypertension is one of the major risk factors for the development of carotid atherosclerosis and peripheral arterial disease with intermittent claudication and aneurysms. However, data are not available to determine whether antihypertensive therapy will alter the course of these processes. Early multicenter trials demonstrated a reduction in deaths from dissecting aortic aneurysms.^199Ra^

## Patients with Hypertension and Other Coexisting Diseases

### Patients With Renal Parenchymal Disease

Pathophysiology. Hypertension may result from any form of renal disease that reduces the number of functioning nephrons, leading to sodium and water retention.^200Pr^ Hypertensive nephrosclerosis is among the most common causes of progressive renal disease, particularly in African Americans.^201X^ Followup of large numbers of men screened for the Multiple Risk Factor Intervention Trial and of male veterans has provided the most conclusive and direct evidence of a relationship between blood pressure and endstage renal disease.^202F,^ ^203F^

Strategies for Slowing Progressive Renal Failure in Patients With Hypertension. Early detection of hypertensive renal damage is essential. Small elevations of serum creatinine reflect significant losses in glomerular filtration rate. Evaluation should include urinalysis to detect proteinuria or hematuria and possibly renal sonography to exclude lower tract obstruction, to exclude autosomal dominant polycystic kidney disease, and to determine the size of the kidneys.^204Pr^ Reversible causes of renal failure always should be sought and treated.

Blood pressure should be controlled to 130/85 mm Hg—or lower (125/75 mm Hg) in patients with proteinuria in excess of 1 gram per 24 hours—with whatever anti-hypertensive therapy is necessary.^75F,^ ^155F^ Reducing dietary sodium to a level lower than that recommended for uncomplicated hypertension (less than 100 mmol per day of sodium) helps control high blood pressure in patients with renal insufficiency.^204Pr^ If dietary protein restriction is instituted, close attention must be paid to total energy (caloric) intake to prevent malnutrition. Restriction of dietary potassium and phosphorus in patients with creatinine clearances below 30 mL per minute is needed to prevent hyperkalemia and to help prevent secondary hyperparathyroidism.

Antihypertensive Drug Recommendations for Patients With Hypertension and Renal Disease. The most important action to slow progressive renal failure is to lower blood pressure to goal. All classes of antihypertensive drugs are effective, and, in most cases, multiple antihypertensive drugs may be needed.^204Pr,^ ^205Pr^ Impressive results have been achieved with ACE inhibitors in patients with type 1 diabetic nephropathy,^206Ra^ in patients with proteinuria greater than 1 gram per 24 hours,^207Ra^ and in patients with renal insufficiency.^208Ra,^ ^209M^ Consequently, patients with hypertension who have renal insufficiency should receive, unless contraindicated, an ACE inhibitor (in most cases, along with a diuretic) to control hypertension and to slow progressive renal failure.^206Ra,^ ^208Ra,^ ^209M^ In patients with a creatinine level of 265.2 μmol/L (3 mg/dL) or greater, ACE inhibitors should be used with caution.

An initial transient decrease in glomerular filtration rate may occur during the first 3 months of treatment as blood pressure is lowered.^207Ra^ If patients are euvolemic and creatinine rises 88.4 μmol/L (1 mg/dL) above baseline levels, creatinine and potassium should be remeasured after several days; if they remain persistently elevated, consideration should be given to the diagnosis of renal artery stenosis and ACE inhibitors or angiotensin II receptor blockers discontinued because these drugs can markedly reduce renal perfusion in patients with bilateral renal artery stenosis or renal artery stenosis to a solitary kidney.^210Pr^

Thiazide diuretics are not effective with advanced renal insufficiency (serum creatinine level of 221.0 μmol/L [2.5 mg/dL] or greater), and loop diuretics are needed (often at relatively large doses). Combining a loop diuretic with a long-acting thiazide diuretic, such as metolazone, is effective in patients resistant to a loop diuretic alone. Potassium-sparing diuretics should be avoided in patients with renal insufficiency.

### Patients With Renovascular Disease

Hemodynamically significant renal artery stenosis may be associated with all stages of hypertension, but it is more commonly found with stage 3 or resistant hypertension and, when bilateral, can lead to reduced kidney function (ischemic nephropathy).^211F^

Clinical clues to renovascular disease include (1) onset of hypertension before age 30, especially without a family history, or recent onset of significant hypertension after age 55; (2) an abdominal bruit, particularly if it continues into diastole and is lateralized; (3) accelerated or resistant hypertension; (4) recurrent (flash) pulmonary edema; (5) renal failure of uncertain cause, especially with a normal urinary sediment; (6) coexisting, diffuse atherosclerotic vascular disease, especially in heavy smokers; and (7) acute renal failure precipitated by antihypertensive therapy, particularly ACE inhibitors or angiotensin II receptor blockers.

In patients with indications of renovascular disease, captopril-enhanced radionuclide renal scan, duplex Doppler flow studies, and magnetic resonance angiography may be used as noninvasive screening tests. Three-dimensional images can be obtained by spiral computed tomography, a technique that unfortunately requires intravenous contrast.^204Pr^ Definitive diagnosis of renovascular disease requires renal angiography, which carries some risk, particularly radio-contrast-induced acute renal failure or atheroembolism in older patients.^212Pr^

Management. In younger patients with fibromuscular dysplasia, results of percutaneous transluminal renal angioplasty (PTRA) have been excellent and comparable to surgical revascularization.^213Re^ Patients with normal renal function and atherosclerotic renal artery stenosis that is focal, unilateral, and nonostial, without widespread vascular disease, are managed similarly to those with fibromuscular dysplasia.^214Pr^ Renal artery stenting has become an important adjunct to PTRA, being used to counteract elastic recoil and to abolish the residual stenosis often observed after PTRA.^215C^

Even though many patients with high-grade renal artery stenosis remain stable for prolonged periods, if blood pressure is well controlled,^216F^ surgical revascularization or PTRA with renal artery stenting may be needed to preserve renal function.^204Pr^

### Patients With Diabetes Mellitus

To detect evidence of autonomic dysfunction and orthostatic hypotension, blood pressure should be measured in the supine, sitting, and standing positions in all patients with diabetes mellitus; automated ambulatory blood pressure monitoring may be especially helpful (see chapter 2).

Antihypertensive drug therapy should be initiated along with lifestyle modifications, especially weight loss, to reduce arterial blood pressure to below 130/85 mm Hg. ACE inhibitors, alpha-blockers, calcium antagonists, and diuretics in low doses are preferred because of fewer adverse effects on glucose homeostasis, lipid profiles, and renal function.^217Pr,^ ^218Pr^ Although beta-blockers may have adverse effects on peripheral blood flow, prolong hypoglycemia, and mask hypoglycemic symptoms, patients with diabetes who are treated with diuretics and beta-blockers experience a similar or greater reduction of CHD and total cardiovascular events compared with persons without diabetes.^219Ra,^ ^220Re^ In patients with diabetic nephropathy, ACE inhibitors are preferred.^206Ra,^ ^221Ra,^ ^222M^ If ACE inhibitors are contraindicated or are not well tolerated, angiotensin II receptor blockers may be considered. Renoprotection also has been shown by the use of a calcium antagonist.^223Ra,^ ^224Ra^

Insulin Resistance. Obese patients with hypertension have resistance to insulin-mediated glucose uptake by skeletal muscle, which can lead to impaired glucose tolerance and type 2 diabetes.^218Pr^ Some nonobese persons with hypertension and persons with normal blood pressure who have first-degree relatives with hypertension also have insulin resistance. It is uncertain whether the higher peripheral insulin levels or the insulin resistance may cause hypertension.^225Pr^ These metabolic disturbances as well as the hypertension respond to weight loss, exercise, insulin-sensitizing agents, vasodilating antihypertensive drugs, and certain lipid-lowering drugs.^226Pr^

### Patients With Dyslipidemia

The common coexistence and increased risk of dyslipidemia and hypertension mandate aggressive management of both conditions.^227Pr^ Because lifestyle modifications are the first approach to the treatment of both conditions, great emphasis must be placed on control of overweight; reduced intake of saturated fat, cholesterol, sodium chloride, and alcohol; and increased physical activity in patients with elevated lipids and high blood pressure.

In high doses, thiazide diuretics and loop diuretics can induce at least short-term increases in levels of total plasma cholesterol, triglycerides, and LDL cholesterol.^228Pr^ Dietary modifications can reduce or eliminate these effects.^77Ra,^ ^229F^ Low-dose thiazide diuretics do not produce these effects.^230Ra^ In the Systolic Hypertension in the Elderly Program and the Hypertension Detection and Follow-up Program, which both used diuretics as initial monotherapy or in combination, the risks for cerebrovascular and coronary events were reduced equally in persons with normal lipid levels and those with elevated lipid levels.^231F,^ ^232F^

Beta-blockers may increase levels of plasma triglycerides transiently and reduce levels of HDL cholesterol.^233F^ Despite this, beta-blockers have been shown to reduce the rate of sudden death, overall mortality, and recurrent myocardial infarction in patients with previous myocardial infarction.^234M^

Alpha-blockers may decrease serum cholesterol concentration to a modest degree and increase HDL cholesterol.^230F^ ACE inhibitors, angio-tensin II receptor blockers, calcium antagonists, and central adrenergic agonists have clinically neutral effects on levels of serum lipids and lipoproteins.^228Pr^

Recent trials have shown that aggressive lipid reduction, especially with beta-hydroxy-beta-methylglutaryl CoA (HMG-CoA) reductase inhibitors (statin drugs), provides both primary and secondary protection against CHD.^235Ra,^ ^236Ra,^ ^237Ra,^ ^238M^ Lifestyle changes and hypolipidemic agents should be used to reach appropriate goals in patients with hypertension and hyperlipidemia. Guidance in the selection of appropriate cholesterol-lowering therapy is available in the guidelines of the National Cholesterol Education Program.^239Pr^

### Patients With Sleep Apnea

Obstructive sleep apnea is characterized by loud snoring and disrupted breathing or gasping during sleep, is more common in patients with hypertension, and is associated with a number of adverse clinical consequences.^240Re^ Undiagnosed sleep apnea may explain the difficulty in controlling high blood pressure in some patients; improved hypertension control has been reported in patients after treatment of their sleep apnea.^241F^

### Patients With Bronchial Asthma or Chronic Airway Disease

Elevated blood pressure is relatively common in acute asthma and may be related to treatment with systemic corticosteroids or beta-agonists.

Beta-blockers and alpha-beta-blockers may exacerbate asthma; therefore, these agents should not be used in patients with asthma except in special circumstances. In addition, the topical ophthalmic application of beta-blockers such as timolol maleate may worsen asthma.

Bronchial reactivity to histamine and kinin remains unchanged with ACE inhibitors, which are safe in most patients with asthma. If a cough related to ACE inhibitor use occurs, angiotensin II receptor blockers are an alternative.

Many over-the-counter medications sold as decongestants and cold and asthma remedies may contain a sympathomimetic agent that can raise blood pressure. Nevertheless, these medications are generally safe when taken in limited doses in patients with hypertension who are receiving adequate antihypertensive therapy.^242F^ Cromolyn sodium, ipratropium bromide, or corticosteroids by inhalation can be used safely for nasal congestion in persons with hypertension.

### Patients With Gout

Hyperuricemia is a frequent finding in patients with untreated hypertension and may reflect a decrease in renal blood flow. In addition, all diuretics can increase serum uric acid levels but rarely induce acute gout.^243F^ In patients with gout, diuretics should be avoided if possible. Diuretic-induced hyperuricemia does not require treatment in the absence of gout or urate stones.

## Patients Undergoing Surgery

Blood pressure of 180/110 mm Hg or greater is associated with a greater risk for perioperative ischemic events. When possible, surgery should be delayed to bring blood pressure down to lower levels.^244Pr^ The perioperative risk for any patient, and especially patients with hypertension, is in part related to the adrenergic arousal before, during, and after surgery.^245^ Those without prior antihypertensive therapy may be best treated with cardioselective beta-blocker therapy before and after surgery.^246Ra^

Adequate potassium supplementation should be provided to correct hypokalemia well in advance of surgery. Surgical candidates who are controlling their blood pressure adequately with medication should be maintained on their regimen until the time of surgery, and therapy should be reinstated as soon as possible after surgery. If oral intake must be interrupted, parenteral therapy with diuretics, adrenergic inhibitors, vasodilators, ACE inhibitors, or transdermal clonidine hydrochloride may be used to prevent the rebound hypertension that may follow sudden discontinuation of some adrenergic-inhibiting agents. Two studies have indicated a need for caution with calcium antagonists because of an increase in surgical bleeding.^247F,^ ^248C^

## Miscellaneous Causes for Increased Blood Pressure

### Cocaine

The majority of cocaine-dependent individuals are normotensive, and no evidence suggests that ongoing cocaine abuse causes chronic hypertension.^249^ However, cocaine abuse must now be considered in all patients presenting to an emergency department with hypertension-related problems. Clues include the presence of chest pain, tachycardia, dilated pupils, combativeness, altered mental status, and seizures. Cocaine may induce severe ischemia from coronary and cerebral vasoconstriction as well as acute renal failure due to rhabdomyolysis.^250^

Nitroglycerin is indicated to reverse cocainerelated coronary vasoconstriction,^251X^ but its antihypertensive efficacy may be inadequate and other parenteral agents may be needed (Table 10). Nonselective beta-blockers such as propranolol should generally be avoided because of the risk of a paradoxical rise in blood pressure as well as coronary vasoconstriction due to the exaggerated effect of catecholamines on unblocked alpha-receptors.^252Ra^

### Amphetamines

Acute amphetamine toxicity is similar to that of cocaine but longer in duration, lasting up to several hours. Cerebral and systemic vasculitis and renal failure may occur. Treatment for amphetamine toxicity is similar to that for cocaine toxicity.

### Immunosuppressive Agents

Immunosuppressive regimens based on cyclosporine, tacrolimus, and steroids increase blood pressure in 50 to 80 percent of recipients of solid organ transplants. When cyclosporine is used alone in nontransplant applications, hypertension develops in 25 to 30 percent of patients. The rise in blood pressure reflects widespread vasoconstriction. Renal vasoconstriction leads to reduced glomerular filtration and enhanced sodium reabsorption. Therapy is based on vasodilation, often including dihydropyridine calcium antagonists. Diuretics are effective but may exaggerate prerenal azotemia and may precipitate gout.^253Pr^

### Erythropoietin

Recombinant human erythropoietin increases blood pressure in 18 to 45 percent of patients when used in the treatment of end-stage renal disease. Hypertension is produced by a rise in systemic vascular resistance, partly related to direct vascular effects of recombinant human erythropoietin, and is not closely related to hematocrit or viscosity. Management includes optimal volume control, antihypertensive agents, and, in some cases, reducing the erythropoietin dose or changing administration from the intravenous to subcutaneous route.

### Other Agents

Hypertension may be induced by numerous other chemical agents and toxins, such as mineralocorticoids and derivatives, anabolic steroids, monoamine oxidase inhibitors, lead, cadmium, and bromocriptine.^254Pr^

## Summary

- Racial and ethnic minority populations are growing segments of our society. The prevalence of hypertension in these populations differs across groups, and control rates are not as good as in the general population. Clinicians should be aware of these management challenges, taking social and cultural factors into account.
- Guidelines are provided for management of children and women with hypertension.
- In older persons, diuretics are preferred and long-acting dihydropyridine calcium antagonists may be considered.
- Specific therapy for patients with left ventricular hypertrophy, coronary artery disease, and heart failure are outlined.
- Patients with renal insufficiency with greater than 1 gram per day of proteinuria should be treated to a therapy blood pressure goal of 125/75 mm Hg; those with less proteinuria should be treated to a blood pressure goal of 130/85 mm Hg. ACE inhibitors have additional renoprotective effects over other antihypertensive agents.
- Patients with diabetes should be treated to a therapy blood pressure goal of below 130/85 mm Hg.
- Hypertension may coexist with various other conditions and may be induced by various pressor agents.