# Prevention and Treatment of High Blood Pressure

## Potential for Primary Prevention of Hypertension

Before considering the active treatment of established hypertension, the even greater need for prevention of disease should be recognized. Without primary prevention, the hypertension problem would never be solved and would rely solely on detection of existing high blood pressure. Primary prevention provides an attractive opportunity to interrupt and prevent the continuing costly cycle of managing hypertension and its complications. Primary prevention reflects a number of realities:

- A significant portion of cardiovascular disease occurs in people whose blood pressure is above the optimal level (120/80 mm Hg) but not so high as to be diagnosed or treated as hypertension.^40Pr,^ ^64F^ A population-wide approach to lowering blood pressure can reduce this considerable burden of risk.
- Active treatment of established hypertension, as carefully as can be provided, poses financial costs and potential adverse effects.
- Most patients with established hypertension do not make sufficient lifestyle changes, do not take medication, or do not take enough medication to achieve control.^24X^
- Even if adequately treated according to current standards, patients with hypertension may not lower their risk to that of persons with normal blood pressure.^67F^
- Blood pressure rise and high blood pressure are not inevitable consequences of aging.^40F^

Therefore, an effective population-wide strategy to prevent blood pressure rise with age and to reduce overall blood pressure levels, even by a little, could affect overall cardiovascular morbidity and mortality as much as or more than that of treating only those with established disease.^29Pr^

Such a population-wide approach has been promulgated.^29Pr^ It is based on lifestyle modifications that have been shown to prevent or delay the expected rise in blood pressure in susceptible people.^68Ra,^ ^69F,^ ^70Ra,^ ^71Ra,^ ^72Ra^ A recent study demonstrated that a diet rich in fruits, vegetables, and low-fat dairy foods, and with reduced saturated and total fats, significantly lowers blood pressure^73Ra^ (see appendix A).

Lifestyle modifications, discussed later in this chapter as being of value in the treatment of established hypertension, could have an even greater impact on disease prevention and should be recommended to the entire population. Modifications that do not require active participation of individuals but that can be provided to the entire population, such as a reduction in the amount of sodium chloride added to processed foods, may be even more effective.

## Goal

The goal of prevention and management of hypertension is to reduce morbidity and mortality by the least intrusive means possible. This may be accomplished by achieving and maintaining SBP below 140 mm Hg and DBP below 90 mm Hg and lower if tolerated, while controlling other modifiable risk factors for cardiovascular disease. Treatment to lower levels may be useful, particularly to prevent stroke,^74Re^ to preserve renal function,^75Ra^ and to prevent or slow heart failure progression.^76F,^ ^77Ra^ The goal may be achieved by lifestyle modification, alone or with pharmacologic treatment.

## Lifestyle Modifications

Lifestyle modifications (Table 6) offer the potential for preventing hypertension, have been shown to be effective in lowering blood pressure, and can reduce other cardiovascular risk factors at little cost and with minimal risk.^73Ra^ Patients should be strongly encouraged to adopt these lifestyle modifications, particularly if they have additional risk factors for premature cardiovascular disease, such as dyslipidemia or diabetes mellitus. Even when lifestyle modifications alone are not adequate in controlling hypertension, they may reduce the number and dosage of antihypertensive medications needed to manage the condition.^77Ra,^ ^78C^ Although the difficulty in achieving and maintaining lifestyle changes is recognized, a systematic team approach utilizing health care professionals and community resources when possible can assist in providing the necessary education, support, and followup.

Table 6 Lifestyle Modifications for Hypertension Prevention and Management

- Lose weight if overweight.; - Limit alcohol intake to no more than 1 oz (30 mL) ethanol (e.g., 24 oz [720 mL] beer, 10 oz [300 mL] wine, or 2 oz [60 mL] 100-proof whiskey) per day or 0.5 oz (15 mL) ethanol per day for women and lighter weight people.; - Increase aerobic physical activity (30 to 45 minutes most days of the week).; - Reduce sodium intake to no more than 100 mmol per day (2.4 g sodium or 6 g sodium chloride).; - Maintain adequate intake of dietary potassium (approximately 90 mmol per day).; - Maintain adequate intake of dietary calcium and magnesium for general health.; - Stop smoking and reduce intake of dietary saturated fat and cholesterol for overall cardiovascular health.

### Weight Reduction

Excess body weight—body mass index (weight in kilograms divided by height in meters, squared) of 27 or greater—is correlated closely with increased blood pressure. The deposition of excess fat in the upper part of the body (visceral or abdominal), as evidenced by a waist circumference of 34 inches (85 cm) or greater in women or 39 inches (98 cm) or greater in men, also has been associated with the risk for hypertension, dyslipidemia, diabetes, and coronary heart disease mortality.^79X^

Weight reduction, of as little as 10 pounds (4.5 kg) reduces blood pressure in a large proportion of overweight persons with hyperten-sion.^72Ra,^ ^80Ra,^ ^81Pr^ In overweight patients with hypertension, weight reduction enhances the blood-pressure-lowering effect of concurrent antihypertensive agents and can significantly reduce concomitant cardiovascular risk factors, such as diabetes and dyslipidemia.^77C^

Therefore, all patients with hypertension who are above their desirable weight should be placed on an individualized, monitored weight reduction program involving caloric restriction and increased physical activity. Recidivism is common and can be discouraging, but persistence may be rewarded by reduction of multiple cardiovascular risk factors and a step-down in antihypertensive drug therapy. Anorectic agents should be used with caution because many can raise blood pressure and some may increase the risk for valvular heart disease^82^ and pulmonary hypertension. ^83Re^

### Moderation of Alcohol Intake

Excessive alcohol intake is an important risk factor for high blood pressure,^69F^ can cause resistance to antihypertensive therapy,^84Ra^ and is a risk factor for stroke.^85Re^ A detailed history of current alcohol consumption should be elicited from patients. Those who drink beverages containing alcohol should be counseled to limit their daily intake to no more than 1 ounce (30 mL) of ethanol—for example, 24 ounces (720 mL) of beer, 10 ounces (300 mL) of wine, or 2 ounces (60 mL) of 100-proof whiskey. Because women absorb more ethanol than men^86C^ and lighter weight people are more susceptible than heavier people to the effects of alcohol, these groups should be counseled to limit their intake to no more than 0.5 ounce (15 mL) of ethanol per day.^87^ Such amounts do not raise blood pressure and have been associated with a lower risk for CHD. Significant hypertension may develop during abrupt withdrawal from heavy alcohol consumption but recedes a few days after alcohol consumption is reduced.

### Physical Activity

Regular aerobic physical activity—adequate to achieve at least a moderate level of physical fitness—can enhance weight loss and functional health status and reduce the risk for cardiovascular disease and all-cause mortality.^88F,^ ^89Ra^ When compared with their more active and fit peers, sedentary individuals with normal blood pressure have a 20- to 50-percent increased risk of developing hypertension.^90F^

Blood pressure can be lowered with moderately intense physical activity (40 to 60 percent of maximum oxygen consumption), such as 30 to 45 minutes of brisk walking most days of the week.^81Pr^ Most people can safely increase their level of physical activity without an extensive medical evaluation. Patients with cardiac or other serious health problems need a more thorough evaluation, often including a cardiac stress test, and may need referral to a specialist or medically supervised exercise program.

### Moderation of Dietary Sodium

Sodium, in the form of sodium chloride or table salt, is linked to levels of blood pressure. Individual response of blood pressure to variation in sodium intake differs widely; as groups, African Americans, older people, and patients with hypertension or diabetes are more sensitive to changes in dietary sodium chloride than are others in the general population.^91Pr^

Epidemiologic data demonstrate a positive association between sodium intake and level of blood pressure.^92X^ Meta-analysis of clinical trials reveals that a reduction of 75 to 100 mmol in sodium intake lowers blood pressure over periods of several weeks to a few years.^93M^ These effects are greater for older persons and those with elevated pressures.^93M,^ ^94M^ An analysis of 17 published randomized controlled trials involving patients age 45 or older with hypertension found an average decrease of 6.3/2.2 mm Hg with a urinary sodium reduction of 95 mmol per day.^94M^ Although concern about severe sodium restriction has been raised in one observational study,^95F^ there is no evidence that lower levels of sodium intake, as achieved in intervention trials, present any safety hazards.

Moreover, a variety of controlled and observational studies suggest that a diet with moderately reduced intake of sodium may be associated with other favorable effects on factors such as ability to reduce the need for antihypertensive medication, reduce diuretic-induced potassium wastage, possibly regress left ventricular hypertrophy, and protect from osteoporosis and renal stones through reduction in urinary calcium excretion.^77C,^ ^78Ra,^ ^96F,^ ^97Ra,^ ^98Pr,^ ^99F,^ ^100Ra,^ ^101Pr^

Seventy-five percent of sodium intake is derived from processed food. Because the average American consumption of sodium is in excess of 150 mmol per day, moderate sodium reduction to a level of no more than 100 mmol per day (approximately 6 grams of sodium chloride or 2.4 grams of sodium per day) is recommended and achievable. With appropriate counseling, patients and their families can learn to read food labels and select foods lower in sodium.^87^ Such items are becoming more readily available in supermarkets and restaurants.

### Potassium Intake

High dietary potassium intake may protect against developing hypertension and improve blood pressure control in patients with hypertension.^102M^ Inadequate potassium intake may increase blood pressure.^69F^ Therefore, an adequate intake of potassium (approximately 90 mmol per day), preferably from food sources such as fresh fruits and vegetables,^73Ra^ should be maintained. If hypokalemia occurs during diuretic therapy, additional potassium may be needed from potassium-containing salt substitutes, potassium supplements, or potassium-sparing diuretics. These agents must be used with caution in patients susceptible to hyperkalemia, including those with renal insufficiency or those receiving angiotensin-converting enzyme (ACE) inhibitors or angiotensin II receptor blockers.

### Calcium Intake

In most epidemiologic studies, low dietary calcium intake is associated with an increased prevalence of hypertension.^103F^ An increased calcium intake may lower blood pressure in some patients with hypertension, but the overall effect is minimal.^104M^ Although it is important to maintain an adequate intake of calcium for general health, there is currently no rationale for recommending calcium supplements to lower blood pressure.

### Magnesium Intake

Although evidence suggests an association between lower dietary magnesium intake and higher blood pressure,^69F^ no convincing data currently justify recommending an increased magnesium intake in an effort to lower blood pressure.

### Other Dietary Factors

Dietary Fats. Dyslipidemia is a major independent risk factor for coronary artery disease; therefore, dietary therapy and, if necessary, drug therapy for dyslipidemia are an important adjunct to antihypertensive treatment. In randomized controlled studies, diets varying in total fat and proportions of saturated to unsaturated fats have had little, if any, effect on blood pressure. Large amounts of omega-3 fatty acids may lower blood pressure; however, some patients experience abdominal discomfort.^105Ra^ One study found no significant effect in preventing hypertension.^71Ra^

Caffeine. Caffeine may raise blood pressure acutely. Tolerance to this pressor effect develops rapidly, and no direct relationship between caffeine intake and elevated blood pressure has been found in most epidemiologic surveys.^69F^

Other Factors. Although recent epidemiologic studies have shown an inverse relationship between dietary protein to blood pressure, no consistent effects have been demonstrated.^106Pr,^ ^107F^ Furthermore, controlled trials of varying proportions of carbohydrate, garlic, or onion in the diet have demonstrated no consistent effects on blood pressure.

### Relaxation and Biofeedback

Emotional stress can raise blood pressure acutely. The role of stress management techniques in treating patients with elevated blood pressure is uncertain. Relaxation therapies and biofeedback have been studied in multiple controlled trials with little effect beyond that seen in the control groups.^108Ra^ A study in African Americans showed significant decreases in SBP and DBP at 3 months.^109Ra^ However, the available literature does not support the use of relaxation therapies for definitive therapy or prevention of hypertension. One study found no effect of stress management on prevention of hypertension.^71Ra^

### Tobacco Avoidance for Overall Cardiovascular Risk Reduction

Cigarette smoking is a powerful risk factor for cardiovascular disease, and avoidance of tobacco in any form is essential. A significant rise in blood pressure accompanies the smoking of each cigarette. Those who continue to smoke may not receive the full degree of protection against cardiovascular disease from antihypertensive therapy.^110F^ The cardiovascular benefits of discontinuing tobacco use can be seen within a year in all age groups.^111Pr^ Smoking cessation information is available from voluntary health organizations and Federal agencies.^112–115^ Smokers must be told repeatedly and unambiguously to stop smoking. The lower amounts of nicotine contained in smoking cessation aids usually will not raise blood pressure; therefore, they may be used with appropriate counseling and behavior interventions.^116Re^ Actions to avoid or minimize weight gain after quitting smoking are often needed.^117F^

Implementation of lifestyle modifications should not delay the start of an effective antihypertensive drug regimen in those at higher risk (Table 5).

## Pharmacologic Treatment

The decision to initiate pharmacologic treatment requires consideration of several factors: the degree of blood pressure elevation, the presence of target organ damage, and the presence of clinical cardiovascular disease or other risk factors (Tables 4 and 5).

### Efficacy

Reducing blood pressure with drugs clearly decreases cardiovascular morbidity and mortality. Protection has been demonstrated for stroke, coronary events, heart failure, progression of renal disease, progression to more severe hypertension, and all-cause mortality^118M,^ ^119Pr^ (Figure 6). Among older persons, treatment of hypertension has been associated with an even more significant reduction in CHD^120M^ (Figure 7).

Figure 6

Meta - Analysis of Randomized, Placebo - Controlled Clinical Trials in Hypertension according to First - Line Treatment Strategy

Figure 7

Combined Results of Five Randomized Trials of Antihypertensive Treatment in the Elderly

These results have been obtained in patients in various countries regardless of sex, age, race, blood pressure level, or socioeconomic status. Therefore, these findings can be generalized with confidence to the entire adult population with high blood pressure.

### Drug Therapy Considerations

Most antihypertensive drugs currently available in the United States are listed in Tables 7 and 8. For most patients, a low dose of the initial drug choice should be used, slowly titrating upward at a schedule dependent on the patient's age, needs, and responses. The optimal formulation should provide 24-hour efficacy with a once-daily dose, with at least 50 percent of the peak effect remaining at the end of the 24 hours. Long-acting formulations that provide 24-hour efficacy are preferred over short-acting agents for many reasons: (1) adherence is better with once-daily dosing; (2) for some agents, fewer tablets incur lower cost; (3) control of hypertension is persistent and smooth rather than intermittent; and (4) protection is provided against whatever risk for sudden death, heart attack, and stroke that is due to the abrupt increase of blood pressure after arising from overnight sleep. Agents with a duration of action beyond 24 hours are attractive because many patients inadvertently miss at least one dose of medication each week. Nonetheless, twice-daily dosing may offer similar control at possibly lower cost.

Table 7 Oral Antihypertensive Drugs*

Drug | Trade Name | Usual Dose Range, Total mg/day* (Frequency per Day) | Selected Side Effects and Comments*
Diuretics (partial list) | | | Short-term: increases cholesterol and glucose levels; biochemical abnormalities: decreases potassium, sodium, and magnesium levels, increases uric acid and calcium levels; rare: blood dyscrasias, photosensitivity, pancreatitis, hyponatremia
Chlorthalidone (G)† | Hygroton | 12.5–50 (1)
Hydrochlorothiazide (G) | Hydrodiuril, Microzide, Esidrix | 12.5–50 (1)
Indapamide | Lozol | 1.25–5 (1) | (Less or no hypercholesterolemia)
Metolazone | Mykrox | 0.5–1.0 (1)
| Zaroxolyn | 2.5–10 (1)
Loop diuretics
Bumetanide (G) | Bumex | 0.5–4 (2–3) | (Short duration of action, no hypercalcemia)
Ethacrynic acid | Edecrin | 25–100 (2–3) | (Only nonsulfonamide diuretic, ototoxicity)
Furosemide (G) | Lasix | 40–240 (2–3) | (Short duration of action, no hypercalcemia)
Torsemide | Demadex | 5–100 (1–2)
Potassium-sparing agents | | | Hyperkalemia
Amiloride hydrochloride (G) | Midamor | 5–10 (1)
Spironolactone (G) | Aldactone | 25–100 (1) | (Gynecomastia)
Triamterene (G) | Dyrenium | 25–100 (1)
Adrenergic inhibitors
Peripheral agents
Guanadrel | Hylorel | 10–75 (2) | (Postural hypotension, diarrhea)
Guanethidine monosulfate | Ismelin | 10–150 (1) | (Postural hypotension, diarrhea)
Reserpine (G)** | Serpasil | 0.05–0.25 (1) | (Nasal congestion, sedation, depression, activation of peptic ulcer)
Central alpha-agonists | | | Sedation, dry mouth, bradycardia,withdrawal hypertension
Clonidine hydrochloride (G) | Catapres | 0.2–1.2 (2–3) | (More withdrawal)
Guanabenz acetate (G) | Wytensin | 8–32 (2)
Guanfacine hydrochloride (G) | Tenex | 1–3 (1) | (Less withdrawal)
Methyldopa (G) | Aldomet | 500–3,000 (2) | (Hepatic and “autoimmune” disorders)
Alpha-blockers | | | Postural hypotension
Doxazosin mesylate | Cardura | 1–16 (1)
Prazosin hydrochloride (G) | Minipress | 2–30 (2–3)
Terazosin hydrochloride | Hytrin | 1–20 (1)
Beta-blockers | | | Bronchospasm, bradycardia, heart failure, may mask insulin-induced hypoglycemia; less serious: impaired peripheral circulation, insomnia, fatigue, decreased exercise tolerance, hypertriglyceridemia (except agents with intrinsic sympathomimetic activity)
Acebutolol§‡ | Sectral | 200–800 (1)
Atenolol (G)§ | Tenormin | 25–100 (1–2)
Betaxolol§ | Kerlone | 5–20 (1)
Bisoprolol fumarate§ | Zebeta | 2.5–10 (1)
Carteolol hydrochloride‡ | Cartrol | 2.5–10 (1)
Metoprolol tartrate (G)§ | Lopressor | 50–300 (2)
Metoprolol succinate§ | Toprol-XL | 50–300 (1)
Nadolol (G) | Corgard | 40–320 (1)
Penbutolol sulfate‡ | Levatol | 10–20 (1)
Pindolol (G)‡ | Visken | 10–60 (2)
Propranolol hydrochloride (G) | Inderal | 40–480 (2)
| Inderal LA | 40–480 (1)
Timolol maleate (G) | Blocadren | 20–60 (2)
Combined alpha- and beta-blockers | | | Postural hypotension, bronchospasm
Carvedilol | Coreg | 12.5–50 (2)
Labetalol hydrochloride (G) | Normodyne, Trandate | 200–1,200 (2)
Direct vasodilators | | | Headaches, fluid retention, tachycardia
Hydralazine hydrochloride (G) | Apresoline | 50–300 (2) | (Lupus syndrome)
Minoxidil (G) | Loniten | 5–100 (1) | (Hirsutism)
Calcium antagonists
Nondihydropyridines | | | Conduction defects, worsening of systolic dysfunction, gingival hyperplasia
Diltiazem hydrochloride | Cardizem SR | 120–360 (2) | (Nausea, headache)
| Cardizem CD, Dilacor XR, Tiazac | 120–360 (1)
Mibefradil dihydrochloride (T-channel calcium antagonist) | Posicor | 50–100 (1) | (No worsening of systolic dysfunction; contraindicated with terfenadine [Seldane], astemizole [Hismanal], and cisapride [Propulsid])
Verapamil hydrochloride | Isoptin SR, Calan SR | 90–480 (2) | (Constipation)
| Verelan, Covera HS | 120–480 (1)
Dihydropyridines | | | Edema of the ankle, flushing, headache, gingival hypertrophy
Amlodipine besylate | Norvasc | 2.5–10 (1)
Felodipine | Plendil | 2.5–20 (1)
Isradipine | DynaCirc | 5–20 (2)
| DynaCirc CR | 5–20 (1)
Nicardipine | Cardene SR | 60–90 (2)
Nifedipine | Procardia XL, Adalat CC | 30–120 (1)
Nisoldipine | Sular | 20–60 (1)
ACE inhibitors | | | Common: cough; rare: angioedema, hyperkalemia, rash, loss of taste, leukopenia
Benazepril hydrochloride | Lotensin | 5–40 (1–2)
Captopril (G) | Capoten | 25–150 (2–3)
Enalapril maleate | Vasotec | 5–40 (1–2)
Fosinopril sodium | Monopril | 10–40 (1–2)
Lisinopril | Prinivil, Zestril | 5–40 (1)
Moexipril | Univasc | 7.5–15 (2)
Quinapril hydrochloride | Accupril | 5–80 (1–2)
Ramipril | Altace | 1.25–20 (1–2)
Trandolapril | Mavik | 1–4 (1)
Angiotensin II receptor blockers | | | Angioedema (very rare), hyperkalemia
Losartan potassium | Cozaar | 25–100 (1–2)
Valsartan | Diovan | 80–320 (1)
Irbesartan | Avapro | 150–300 (1)

* These dosages may vary from those listed in the Physicians' Desk Reference (51st edition), which may be consulted for additional information. The listing of side effects is not all-inclusive, and side effects are for the class of drugs except where noted for individual drugs (in parentheses); clinicians are urged to refer to the package insert for a more detailed listing.

† (G) indicates generic available.

‡ Has intrinsic sympathomimetic activity.

§ Cardioselective.

** Also acts centrally.

Table 8 Combination Drugs for Hypertension

Drug | Trade Name
Beta-adrenergic blockers and diuretics
Atenolol, 50 or 100 mg/chlorthalidone, 25 mg | Tenoretic
Bisoprolol fumarate, 2.5, 5, or 10 mg/hydrochlorothiazide, 6.25 mg | Ziac*
Metoprolol tartrate, 50 or 100 mg/hydrochlorothiazide, 25 or 50 mg | Lopressor HCT
Nadolol, 40 or 80 mg/bendroflumethiazide, 5 mg | Corzide
Propranolol hydrochloride, 40 or 80 mg/hydrochlorothiazide, 25 mg | Inderide
Propranolol hydrochloride (extended release), 80, 120, or 160 mg/hydrochlorothiazide, 50 mg | Inderide LA
Timolol maleate, 10 mg/hydrochlorothiazide, 25 mg | Timolide
ACE inhibitors and diuretics
Benazepril hydrochloride, 5, 10, or 20 mg/hydrochlorothiazide, 6.25, 12.5, or 25 mg | Lotensin HCT
Captopril, 25 or 50 mg/hydrochlorothiazide, 15 or 25 mg | Capozide*
Enalapril maleate, 5 or 10 mg/hydrochlorothiazide, 12.5 or 25 mg | Vaseretic
Lisinopril, 10 or 20 mg/hydrochlorothiazide, 12.5 or 25 mg | Prinzide, Zestoretic
Angiotensin II receptor antagonists and diuretics
Losartan potassium, 50 mg/hydrochlorothiazide, 12.5 mg | Hyzaar
Calcium antagonists and ACE inhibitors
Amlodipine besylate, 2.5 or 5 mg/benazepril hydrochloride, 10 or 20 mg | Lotrel
Diltiazem hydrochloride, 180 mg/enalapril maleate, 5 mg | Teczem
Verapamil hydrochloride (extended release), 180 or 240 mg/trandolapril, 1, 2, or 4 mg | Tarka
Felodipine, 5 mg/enalapril maleate, 5 mg | Lexxel
Other combinations
Triamterene, 37.5, 50, or 75 mg/hydrochlorothiazide, 25 or 50 mg | Dyazide, Maxide
Spironolactone, 25 or 50 mg/hydrochlorothiazide, 25 or 50 mg | Aldactazide
Amiloride hydrochloride, 5 mg/hydrochlorothiazide, 50 mg | Moduretic
Guanethidine monosulfate, 10 mg/hydrochlorothiazide, 25 mg | Esimil
Hydralazine hydrochloride, 25, 50, or 100 mg/hydrochlorothiazide, 25 or 50 mg | Apresazide
Methyldopa, 250 or 500 mg/hydrochlorothiazide, 15, 25, 30, or 50 mg | Aldoril
Reserpine, 0.125 mg/hydrochlorothiazide, 25 or 50 mg | Hydropres
Reserpine, 0.10 mg/hydralazine hydrochloride, 25 mg/hydrochlorothiazide, 15 mg | Ser-Ap-Es
Clonidine hydrochloride, 0.1, 0.2, or 0.3 mg/chlorthalidone, 15 mg | Combipres
Methyldopa, 250 mg/chlorothiazide, 150 or 250 mg | Aldochlor
Reserpine, 0.125 or 0.25 mg/chlorthalidone, 25 or 50 mg | Demi-Regroton
Reserpine, 0.125 or 0.25 mg/chlorothiazide, 250 or 500 mg | Diupres
Prazosin hydrochloride, 1, 2, or 5 mg/polythiazide, 0.5 mg | Minizide

* Approved for initial therapy.

Newly developed formulations provide additional medication choices. For example, combinations of low doses of two agents from different classes have been shown to provide additional antihypertensive efficacy, thereby minimizing the likelihood of dose-dependent adverse effects (Table 8). Very low doses of a diuretic (e.g., 6.25 mg of hydrochlorothiazide) can potentiate the effect of the other agent without producing adverse metabolic effects.^121Ra^ Low-dose combinations with an ACE inhibitor and a nondihydropyridine calcium antagonist may reduce proteinuria more than either drug alone.^122Pr^ Combinations of a dihydropyridine calcium antagonist and an ACE inhibitor induce less pedal edema than does the calcium antagonist alone.^123Ra^ In some instances, drugs with similar modes of action may provide additive effects, such as metolazone and a loop diuretic in renal failure.

ACE inhibitors have been shown to provide beneficial effects in a variety of hypertension-related processes including heart failure from systolic dysfunction and nephropathy (see chapter 4). The recently introduced angiotensin II receptor blockers produce hemodynamic effects similar to those of ACE inhibitors while avoiding the most common adverse effect, dry cough. However, in the absence of data documenting equal long-term cardiac and renal protection in patients with these conditions, angiotensin II receptor blockers should be used primarily in patients in whom ACE inhibitors are indicated but who are unable to tolerate them.

Some antihypertensive agents—such as direct-acting smooth-muscle vasodilators, central alpha_2_-agonists, and peripheral adrenergic antagonists—are not well suited for initial monotherapy because they produce annoying adverse effects in many patients. Reserpine has a uniquely prolonged therapeutic effect and is better tolerated in low doses (0.05 to 0.10 mg per day); however, patients and their families still should be warned about the possibility of depression. The direct-acting smooth-muscle vasodilators (e.g., hydralazine hydrochloride, minoxidil) often induce reflex sympathetic stimulation of the cardiovascular system and fluid retention.

Immediate-release nifedipine has precipitated ischemic events^124Pr^ and, in large doses, may increase coronary mortality in patients who have had a myocardial infarction.^125M^ Therefore, this agent should be used only with great caution, if at all. There have been inconsistent reports regarding adverse health effects of short-acting or immediate-release formulations of nifedipine, diltiazem hydrochloride, and verapamil hydro-chloride.^126Pr,^ ^127^ Randomized controlled trials are now in progress with long-acting types and formulations of calcium antagonists approved for treatment of hypertension. In the meantime, specific recommendations are provided in Tables 9 and 10 and Figure 8.

Table 9 Considerations for Individualizing Antihypertensive Drug Therapy*

Indication | Drug Therapy
Compelling Indications Unless Contraindicated
Diabetes mellitus (type 1) with proteinuria | ACE I
Heart failure | ACE I, diuretics
Isolated systolic hypertension (older patients) | Diuretics (preferred), CA (long-acting DHP)
Myocardial infarction | Beta-blockers (non-ISA), ACE I (with systolic dysfunction)
May Have Favorable Effects on Comorbid Conditions†
Angina | Beta-blockers, CA
Atrial tachycardia and fibrillation | Beta-blockers, CA (non-DHP)
Cyclosporine-induced hypertension (caution with the dose of cyclosporine) | CA
Diabetes mellitus (types 1 and 2) with proteinuria | ACE I (preferred), CA
Diabetes mellitus (type 2) | Low-dose diuretics
Dyslipidemia | Alpha-blockers
Essential tremor | Beta-blockers (non-CS)
Heart failure | Carvedilol, losartan potassium
Hyperthyroidism | Beta-blockers
Migraine | Beta-blockers (non-CS), CA (non-DHP)
Myocardial infarction | Diltiazem hydrochloride, verapamil hydrochloride
Osteoporosis | Thiazides
Preoperative hypertension | Beta-blockers
Prostatism (BPH) | Alpha-blockers
Renal insufficiency (caution in renovascular hypertension and creatinine >265.2 mmol/L [3 mg/dL]) | ACE I
May Have Unfavorable Effects on Comorbid Conditions†‡
Bronchospastic disease | Beta-blockers§
Depression | Beta-blockers, central alpha-agonists, reserpine§
Diabetes mellitus (types 1 and 2) | Beta-blockers, high-dose diuretics
Dyslipidemia | Beta-blockers (non-ISA), diuretics (high-dose)
Gout | Diuretics
2° or 3° heart block | Beta-blockers,§ CA (non-DHP)§
Heart failure | Beta-blockers (except carvedilol), CA (except amlodipine besylate, felodipine)
Liver disease | Labetalol hydrochloride, methyldopa§
Peripheral vascular disease | Beta-blockers
Pregnancy | ACE I,§ angiotensin II receptor blockers§
Renal insufficiency | Potassium-sparing agents
Renovascular disease | ACE I, angiotensin II receptor blockers

* For initial drug therapy recommendations, see Figure 8. For references, see chapter 4, Physicians' Desk Reference(51st edition), and Kaplan and Gifford.^134^ ACE I indicates angiotensin-converting enzyme inhibitors; BPH, benign prostatic hyperplasia; CA, calcium antagonists; DHP, dihydropyridine; ISA, intrinsic sympathomimetic activity; MI, myocardial infarction; and non-CS, noncardioselective.

† Conditions and drugs are listed in alphabetical order.

‡ These drugs may be used with special monitoring unless contraindicated.

§ Contraindicated.

Table 10 Parenteral Drugs for Treatment of Hypertensive Emergencies*

Drug | Does† | Onset of Action | Duration of Action | Adverse Effects‡ | Special Indications
Vasodilators
Sodium nitroprusside | 0.25–10 μg/kg per min as IV infusion§ (maximal dose for 10 min only) | Immediate | 1–2 min | Nausea, vomiting, muscle twitching, sweating, thiocyanate and cyanide intoxication | Most hypertensive emergencies; caution with high intracranial pressure or azotemia
Nicardipine hydrochloride | 5–15 mg/h IV | 5–10 min | 1–4 h | Tachycardia, headache, flushing, local phlebitis | Most hypertensive emergencies except acute heart failure; caution with coronary ischemia
Fenoldopam mesylate | 0.1–0.3 μg/kg per min IV infusion | <5 min | 30 min | Tachycardia, headache, nausea, flushing | Most hypertensive emergencies; caution with glaucoma
Nitroglycerin | 5–100 μg/min as IV infusion§ | 2–5 min | 3–5 min | Headache, vomiting, methemoglobinemia, tolerance with prolonged use | Coronary ischemia
Enalaprilat | 1.25–5 mg every 6 h IV | 15–30 min | 6 h | Precipitous fall in pressure in high-renin states; response variable | Acute left ventricular failure; avoid in acute myocardial infarction
Hydralazine hydrochloride | 10–20 mg IV | 10–20 min | 3–8 h | Tachycardia, flushing, headache, vomiting, aggravation of angina | Eclampsia
| 10–50 mg IM | 20–30 min
Diazoxide | 50–100 mg IV bolus repeated, or 15–30 mg/min infusion | 2–4 min | 6–12 h | Nausea, flushing, tachycardia, chest pain | Now obsolete; when no intensive monitoring available
Adrenergic inhibitors
Labetalol hydrochloride | 20–80 mg IV bolus every 10 min 0.5–2.0 mg/min IV infusion | 5–10 min | 3–6 h | Vomiting, scalp tingling, burning in throat, dizziness, nausea, heart block, orthostatic hypotension | Most hypertensive emergencies except acute heart failure
Esmolol hydrochloride | 250–500 μg/kg/min for 1 min, then 50–100 μg/kg/min for 4 min; may repeat sequence | 1–2 min | 10–20 min | Hypotension, nausea | Aortic dissection, perioperative
Phentolamine | 5–15 mg IV | 1–2 min | 3–10 min | Tachycardia, flushing, headache | Catecholamine excess

* These doses may vary from those in the Physicians' Desk Reference(51st edition).

† IV indicates intravenous; IM, intramuscular.

‡ Hypotension may occur with all agents.

§ Require special delivery system.

Figure 8

Algorithm for the Treatment of Hypertension

### Special Considerations

Special considerations in the selection of initial therapy include demographic characteristics, concomitant diseases that may be beneficially or adversely affected by the antihypertensive agent chosen (Table 9), quality of life, cost, and use of other drugs that may lead to drug interactions (Table 11). When choosing a certain drug for its favorable effect on comorbidity, clinicians should be aware that reduction of long-term cardiovascular morbidity and mortality may not have been demonstrated.^118M^

Table 11 Selected Drug Interactions with Antihypertensive Therapy*

Class of Agent | Increase Efficacy | Decrease Efficacy | Effect on Other Drugs
Diuretics | - Diuretics that act at different sites in the nephron (e.g., furosemide + thiazides) | - Resin-binding agents; - NSAIDs; - Steroids | - Diuretics raise serum lithium levels.; - Potassium-sparing agents may exacerbate hyperkalemia due to ACE inhibitors.
Beta-blockers | - Cimetidine (hepatically metabolized beta-blockers); - Quinidine (hepatically metabolized beta-blockers); - Food (hepatically metabolized beta-blockers) | - NSAIDs; - Withdrawal of clonidine; - Agents that induce hepatic enzymes, including rifampin and phenobarbital | - Propranolol hydrochloride induces hepatic enzymes to increase clearance of drugs with similar metabolic pathways.; - Beta-blockers may mask and prolong insulin-induced hypoglycemia.; - Heart block may occur with nondihydropyridine calcium antagonists.; - Sympathomimetics cause unopposed alpha-adrenoceptor-mediated vasoconstriction.; - Beta-blockers increase angina- inducing potential of cocaine.
ACE inhibitors | - Chlorpromazine or clozapine | - NSAIDs; - Antacids; - Food decreases absorption (moexipril) | - ACE inhibitors may raise serum lithium levels.; - ACE inhibitors may exacerbate hyperkalemic effect of potassium- sparing diuretics.
Calcium antagonists | - Grapefruit juice (some dihydropyridines); - Cimetidine or ranitidine (hepatically metabolized calcium antagonists) | - Agents that induce hepatic enzymes, including rifampin and phenobarbital | - Cyclosporine levels increase† with diltiazem hydrochloride, verapamil hydrochloride, mibefradil dihydrochloride, or nicardipine hydrochloride (but not felodipine, isradipine, or nifedipine).; - Nondihydropyridines increase levels of other drugs metabolized by the same hepatic enzyme system, including digoxin, quinidine, sulfonylureas, and theophylline.; - Verapamil hydrochloride may lower serum lithium levels.
Alpha-blockers | | | - Prazosin may decrease clearance of verapamil hydrochloride.
Central alpha_2_-agonists and peripheral neuronal blockers | | - Tricyclic antidepressants (and probably phenothiazines); - Monoamine oxidase inhibitors; - Sympathomimetics or phenothiazines antagonize guanethidine monosulfate or guanadrel sulfate; - Iron salts may reduce methyldopa absorption | - Methyldopa may increase serum lithium levels.; - Severity of clonidine hydrochloride withdrawal may be increased by beta-blockers.; - Many agents used in anesthesia are potentiated by clonidine hydrochloride.

* For initial drug therapy recommendations, see Figure 8. See also Physicians' Desk Reference(51st edition) and Cardiovascular Pharmacotherapeutics(New York: McGraw Hill), 1997. NSAIDs indicate nonsteroidal anti-inflammatory drugs; ACE, angiotensin-converting enzyme.

† This is a clinically and economically beneficial drug-drug interaction because it both retards progression of accelerated atherosclerosis in heart transplant recipients and reduces the required daily dose of cyclosporine.

Demographics. Neither sex nor age usually affects responsiveness to various agents.^128M^ In general, hypertension in African Americans is more responsive to monotherapy with diuretics and calcium antagonists than to beta-blockers or ACE inhibitors.^129Ra^ However, if a beta-blocker or ACE inhibitor is needed for other therapeutic benefits, differences in efficacy usually can be overcome with reduction of salt intake, higher doses of the drug, or addition of a diuretic.

Concomitant Diseases and Therapies. Antihypertensive drugs may worsen some diseases and improve others (Table 9). Selection of an antihypertensive agent that also treats a coexisting disease will simplify therapeutic regimens and reduce costs.

Quality of Life. Although antihypertensive drugs may cause adverse effects in some patients (Table 7), quality of life is maintained and possibly improved by any of the agents recommended for initial therapy.^130Ra^

Physiological and Biochemical Measure-ments. Some clinicians have found certain physiological and biochemical measurements (e.g., body weight, heart rate, plasma renin activity, hemodynamic measurements) to be helpful in choosing specific therapy.

Economic Considerations. The cost of therapy may be a barrier to controlling high blood pressure and should be an important consideration in selecting antihypertensive medication. Generic formulations are acceptable. Nongeneric newer drugs are usually more expensive than diuretics or beta-blockers. If newer agents eventually prove to be equally effective, then cost should be considered in choosing them for initial therapy; if they prove to be more effective, then cost should be a secondary consideration. Treatment costs include not only the price of drugs but also the expense of routine or special laboratory tests, supplemental therapies, office visits, and time lost from work for visits to physicians' offices. The costs of medications may be reduced by using combination tablets and generic formulations. Patients should be advised to check prices at different sources. Some larger tablets can be divided, saving money when larger doses cost little more than smaller doses. Some sustained-release formulations should not be divided because cutting the tablet eliminates the sustained-release function.

Managed Care. Because high blood pressure is so common, its management requires a major commitment from clinicians and managed care organizations. This commitment will need to expand even further because the majority of patients with hypertension do not have adequately controlled blood pressure (see chapter 1) and additional demands will develop from the projected increase in numbers of persons with hypertension due to the aging of the population. However, the cost of managing hypertension is lower overall than the sum of direct and indirect costs that may be avoided by reducing hypertension-associated heart disease, stroke, and renal failure, especially because these adverse events often lead to expensive hospitalizations, surgical procedures, and high-cost technologies.^131Pr,^ ^132Pr,^ ^133Pr^ Randomized controlled trials have demonstrated that these reductions occur in a relatively short time and are sustained for years.

Managed care programs offer the opportunity for a coordinated approach to care, using various health care professionals and featuring an appropriate frequency of office visits, short waiting times, supportive patient counseling, and controlled formularies. The outcomes of the management of hypertension will need to be monitored, in keeping with the requirements of organizations that monitor quality, such as the Health Plan Employer Data and Information Set (HEDIS). These outcomes may be divided into three categories: immediate (e.g., blood pressure levels, percentage of adherence to therapy), intermediate (e.g., cardiac or renal function, health resource utilization), and long-term (e.g., morbidity and mortality, cost-effectiveness).

Hypertension specialists may play an important role in providing more cost-effective management of high blood pressure by adapting national guidelines for local implementation, providing guidance for new drugs and diagnostic methods, and managing patients with identifiable causes of hypertension, resistance to therapy, or complex concomitant conditions.

Drug Interactions. As shown in Table 11, some drug interactions may be helpful. For example, diuretics that act on different sites in the nephron, such as furosemide and thiazides, increase natiuresis and diuresis, and certain calcium antagonists reduce the required amount of cyclosporine. Other interactions are deleterious: nonsteroidal anti-inflammatory drugs (NSAIDs) may blunt the action of diuretics, beta-blockers, and ACE inhibitors.

### Dosage and Followup

Therapy for most patients (uncomplicated hypertension, stages 1 and 2) should begin with the lowest dosage listed in Table 7 to prevent adverse effects of too great or too abrupt a reduction in blood pressure. If blood pressure remains uncontrolled after 1 to 2 months, the next dosage level should be prescribed. It may take months to control hypertension adequately while avoiding adverse effects of therapy. Most antihypertensive medications can be given once daily, and this should be the goal to improve patient adherence. Home or office blood pressure measurement in the early morning before patients have taken their daily dose is useful to ensure adequate modulation of the surge in blood pressure after arising. Measurements in the late afternoon or evening help monitor control across the day. Treatment goals based on out-of-office measurements should be lower than those based on office recordings^45Pr^ (see chapter 2).

### Initial Drug Therapy

When the decision has been made to begin antihypertensive therapy (Table 5) and if there are no indications for another type of drug, a diuretic or beta-blocker should be chosen because numerous randomized controlled trials have shown a reduction in morbidity and mortality with these agents (Figures 6 and 7).

As shown in Table 9 and Figure 8, there are compelling indications for specific agents in certain clinical conditions, based on outcomes data from RCTs. In other situations where outcomes data are not yet available, there are indications for other agents and the choice should be individualized, using the agent that most closely fits the patient's needs.^134Pr^

If the response to the initial drug choice is inadequate after reaching the full dose, two options for subsequent therapy should be considered (see Figure 8 for treatment algorithm):

- If the patient is tolerating the first choice well, add a second drug from another class.
- If the patient is having significant adverse effects or no response, substitute an agent from another class.

If a diuretic is not chosen as the first drug, it is usually indicated as a second-step agent because its addition will enhance the effects of other agents. If addition of a second agent controls blood pressure satisfactorily, an attempt to withdraw the first agent may be considered.^135F^

Before proceeding to each successive treatment step, clinicians should consider possible reasons for lack of responsiveness to therapy, including those listed in Table 12.

Table 12 Causes of Inadequate Responsiveness to Therapy

Pseudoresistance
“White-coat hypertension” or office elevations
Pseudohypertension in older patients
Use of regular cuff on very obese arm
Nonadherence to therapy
(See Table 13)
Volume overload
Excess salt intake
Progressive renal damage (nephrosclerosis)
Fluid retention from reduction of blood pressure
Inadequate diuretic therapy
Drug-related causes
Doses too low
Wrong type of diuretic
Inappropriate combinations
Rapid inactivation (e.g., hydralazine)
Drug actions and interactions
Sympathomimetics
Nasal decongestants
Appetite suppressants
Cocaine and other illicit drugs
Caffeine
Oral contraceptives
Adrenal steroids
Licorice (as may be found in chewing tobacco)
Cyclosporine, tacrolimus
Erythropoietin
Antidepressants
Nonsteroidal anti-inflammatory drugs
Associated conditions
Smoking
Increasing obesity
Sleep apnea
Insulin resistance/hyperinsulinemia
Ethanol intake of more than 1 oz (30 mL) per day
Anxiety-induced hyperventilation or panic attacks
Chronic pain
Intense vasoconstriction (arteritis)
Organic brain syndrome (e.g., memory deficit)
Identifiable causes of hypertension
(See chapter 2)

### High-Risk Patients

Although similar general approaches are advocated for all patients with hypertension, modifications may be needed for those with stage 3 hypertension, those in risk group C, or those at especially high risk for a coronary event or stroke (Table 5). Drug therapy should begin with minimal delay. Although some patients may respond adequately to a single drug, it is often necessary to add a second or third agent after a short interval if control is not achieved. The intervals between changes in the regimen should be decreased, and the maximum dose of some drugs may be increased. In some patients, it may be necessary to start treatment with more than one agent. Patients with average SBP of 200 mm Hg or greater and average DBP of 120 mm Hg or greater require more immediate therapy and, if symptomatic target organ damage is present, may require hospitalization.

### Step-Down Therapy

An effort to decrease the dosage and number of antihypertensive drugs should be considered after hypertension has been controlled effectively for at least 1 year. The reduction should be made in a deliberate, slow, and progressive manner. Step-down therapy is more often successful in patients who also are making lifestyle modifications.^80Ra^ Patients whose drugs have been discontinued should have scheduled followup visits because blood pressure usually rises again to hypertensive levels, sometimes months or years after discontinuance, especially in the absence of sustained improvements in lifestyle.

### J-Curve Hypothesis

Concerns have been raised that lowering DBP too much may increase the risk for coronary events by lowering diastolic perfusion pressure in the coronary circulation—the so-called J-curve hypothesis.^136Pr^ The J-curve also has been detected in the placebo group of clinical trials of older persons with hypertension.^137F,^ ^138F^ The J-curve concern may be more relevant to patients with both hypertension and preexisting coronary disease^136Pr^ and to those with pulse pressure greater than 60 mm Hg.^139F^ On the other hand, data support a progressive reduction in both cerebrovascular disease^74Re^ and renal disease^75F^ with even greater reductions in blood pressure. All available evidence supports the value of the reduction of DBP and SBP at all ages to the levels achieved in clinical trials—usually DBP to below 90 mm Hg and SBP to below 140 mm Hg in patients with isolated systolic hypertension.^140Ra,^ ^141Pr,^ ^142Ra^ In trials of persons with isolated systolic hypertension, no increase in cardiovascular morbidity and mortality was observed, despite further reductions of DBP.

## Considerations for Adherence to Therapy

Poor adherence to antihypertensive therapy remains a major therapeutic challenge^143Pr^ contributing to the lack of adequate control in more than two-thirds of patients with hypertension (see chapter 1). As attempts to improve adherence are made, patients have the right and responsibility to be active and well-informed participants in their own care and to achieve maximal physical and emotional well-being. Health care professionals have the responsibility to provide patients with complete and accurate information about their health status, allowing patients the opportunity to participate in their care and to achieve goal blood pressure.

### Followup Visits

Achieving and maintaining target blood pressure often requires continuing encouragement for lifestyle modification and medication adjustment. Most patients should be seen within 1 to 2 months after the initiation of therapy to determine the adequacy of hypertension control, the degree of patient adherence, and the presence of adverse effects. Associated medical problems—including target organ damage, other major risk factors, and laboratory test abnormalities—also play a part in determining the frequency of patient followup. Visits to other members of the health care team may provide opportunities for more frequent followup.^37Pr^ Once blood pressure is stabilized, followup at 3- to 6-month intervals (depending on patient status) is generally appropriate. In some patients, particularly older persons and those with orthostatic symptoms, monitoring should include blood pressure measurement in the seated position and, to recognize postural hypotension, after standing quietly for 2 to 5 minutes.

### Strategies for Improving Adherence to Therapy and Control of High Blood Pressure

Various strategies may improve adherence significantly (Table 13). The choice and application of specific strategies depend on individual patient characteristics, and health care providers are not expected to apply all of them at any one time or to all patients. In particular, pharmacists should be encouraged to monitor patients' use of medications, to provide information about potential adverse effects, and to avoid drug interactions. Nurse-managed clinics offer attractive opportunities to improve adherence and outcomes.^37Pr,^ ^144Pr^ The services of other members of the health care team, such as those who provide counseling in nutrition or exercise, should be used.

Table 13 General Guidelines to Improve Patient Adherence to Antihypertensive Therapy

- Be aware of signs of patient nonadherence to antihypertensive therapy.; - Establish the goal of therapy: to reduce blood pressure to nonhypertensive levels with minimal or no adverse effects.; - Educate patients about the disease, and involve them and their families in its treatment. Have them measure blood pressure at home.; - Maintain contact with patients; consider telecommunication.; - Keep care inexpensive and simple.; - Encourage lifestyle modifications.; - Integrate pill-taking into routine activities of daily living.; - Prescribe medications according to pharmacologic principles, favoring long-acting formulations.; - Be willing to stop unsuccessful therapy and try a different approach.; - Anticipate adverse effects, and adjust therapy to prevent, minimize, or ameliorate side effects.; - Continue to add effective and tolerated drugs, stepwise, in sufficient doses to achieve the goal of therapy.; - Encourage a positive attitude about achieving therapeutic goals.; - Consider using nurse case management.

### Resistant Hypertension

Hypertension should be considered resistant if blood pressure cannot be reduced to below 140/90 mm Hg in patients who are adhering to an adequate and appropriate triple-drug regimen that includes a diuretic, with all three drugs prescribed in near maximal doses. For older patients with isolated systolic hypertension, resistance is defined as failure of an adequate triple-drug regimen to reduce SBP to below 160 mm Hg.

Of the various causes of true resistance listed in Table 12, one of the most common is volume overload due to inadequate diuretic therapy.^145Pr^ Frequently, a cause for resistance can be recognized and overcome. However, if goal blood pressure cannot be achieved without intolerable adverse effects, even suboptimal reduction of blood pressure contributes to decreased morbidity and mortality. Patients who have resistant hypertension or who are unable to tolerate antihypertensive therapy may benefit from referral to a hypertension specialist.

## Hypertensive Crises: Emergencies and Urgencies

Hypertensive emergencies are those rare situations that require immediate blood pressure reduction (not necessarily to normal ranges) to prevent or limit target organ damage. Examples include hypertensive encephalopathy, intracranial hemorrhage, unstable angina pectoris, acute myocardial infarction, acute left ventricular failure with pulmonary edema, dissecting aortic aneurysm, or eclampsia. Hypertensive urgencies are those situations in which it is desirable to reduce blood pressure within a few hours. Examples include upper levels of stage 3 hypertension, hypertension with optic disk edema, progressive target organ complications, and severe perioperative hypertension. Elevated blood pressure alone, in the absence of symptoms or new or progressive target organ damage, rarely requires emergency therapy.

Parenteral drugs for hypertensive emergencies are listed in Table 10. Most hypertensive emergencies are treated initially with parenteral administration of an appropriate agent. Hypertensive urgencies can be managed with oral doses of drugs with relatively fast onset of action. The choices include loop diuretics, beta-blockers, ACE inhibitors, alpha_2_-agonists, or calcium antagonists.

The initial goal of therapy in hypertensive emergencies is to reduce mean arterial blood pressure by no more than 25 percent (within minutes to 2 hours), then toward 160/100 mm Hg within 2 to 6 hours, avoiding excessive falls in pressure that may precipitate renal, cerebral, or coronary ischemia. Although sublingual administration of fast-acting nifedipine has been widely used for this purpose, several serious adverse effects have been reported with its use^124Pr^ and the inability to control the rate or degree of fall in blood pressure makes this agent unacceptable. The routine use of sublingual nifedipine whenever blood pressure rises beyond a predetermined level in postoperative or nursing home patients is also not appropriate. Rather, the proximate causes of the elevated blood pressure, such as pain or a distended urinary bladder, should be addressed. Blood pressure should be monitored over 15- to 30-minute intervals; if it remains greater than 180/120 mm Hg, one of the previously mentioned oral agents may be given. If such high levels of blood pressure are frequent, adequate doses of long-acting agents should be provided.

## Summary

- Modifying lifestyles in populations can have a major protective effect against high blood pressure and cardiovascular disease.
- Lowering blood pressure decreases deaths from stroke, coronary events, and heart failure; slows progression of renal failure; prevents progression to more severe hypertension; and reduces all-cause mortality.
- A diuretic and/or a beta-blocker should be chosen as initial therapy unless there are compelling or specific indications for another drug.
- Management strategies can improve adherence through the use of multidisciplinary teams.
- The reductions in cardiovascular events demonstrated in randomized controlled trials have important implications for managed care organizations.
- Strategies for managing hypertensive emergencies and urgencies are described.