# Blood Pressure Measurement and Clinical Evaluation

Hypertension is defined as systolic blood pressure (SBP) of 140 mm Hg or greater, diastolic blood pressure (DBP) of 90 mm Hg or greater, or taking antihypertensive medication. The objective of identifying and treating high blood pressure is to reduce the risk of cardiovascular disease and associated morbidity and mortality. To that end, it is useful to provide a classification of adult blood pressure for the purpose of identifying high-risk individuals and to provide guidelines for followup and treatment.

The positive relationship between SBP and DBP and cardiovascular risk has long been recognized. This relationship is strong, continuous, graded, consistent, independent, predictive, and etiologically significant for those with and without coronary heart disease.^40,^ ^41^Therefore, although classification of adult blood pressure is somewhat arbitrary, it is useful to clinicians who must make treatment decisions based on a constellation of factors including the actual level of blood pressure. Table 2 provides a classification of blood pressure for adults (age 18 and older). These criteria are for individuals who are not taking antihypertensive medication and who have no acute illness. This classification is based on the average of two or more blood pressure readings taken in accordance with the following recommendations at each of two or more visits after an initial screening visit. When SBP and DBP fall into different categories, the higher category should be selected to classify the individual's blood pressure. The classification is slightly modified from the JNC V report in that stage 3 and stage 4 hypertension are now combined because of the relative infrequency of stage 4 hypertension.

Table 2 Classification of Blood Pressure for Adults Age 18 and Older*

Category | Systolic (mm Hg) | | Diastolic (mm Hg)
Optimal^†^ | <120 | and | <80
Normal | <130 | and | <85
High-normal | 130–139 | or | 85–89
Hypertension^‡^
Stage 1 | 140–159 | or | 90–99
Stage 2 | 160–179 | or | 100–109
Stage 3 | ≥180 | or | ≥110

* Not taking antihypertensive drugs and not acutely ill. When systolic and diastolic blood pressures fall into different categories, the higher category should be selected to classify the individual's blood pressure status. For example, 160/92 mm Hg should be classified as stage 2 hypertension, and 174/120 mm Hg should be classified as stage 3 hypertension. Isolated systolic hypertension is defined as SBP of 140 mm Hg or greater and DBP below 90 mm Hg and staged appropriately (e.g., 170/82 mm Hg is defined as stage 2 isolated systolic hypertension). In addition to classifying stages of hypertension on the basis of average blood pressure levels, clinicians should specify presence or absence of target organ disease and additional risk factors. This specificity is important for risk classification and treatment (see Table 5).

† Optimal blood pressure with respect to cardiovascular risk is below 120/80 mm Hg. However, unusually low readings should be evaluated for clinical significance.

‡ Based on the average of two or more readings taken at each of two or more visits after an initial screening.

## Detection and Confirmation

Hypertension detection begins with proper blood pressure measurements, which should be obtained at each health care encounter. Repeated blood pressure measurements will determine whether initial elevations persist and require prompt attention or have returned to normal and need only periodic surveillance. Blood pressure should be measured in a standardized fashion using equipment that meets certification criteria.^42^ The following techniques are recommended:

- Patients should be seated in a chair with their backs supported and their arms bared and supported at heart level. Patients should refrain from smoking or ingesting caffeine during the 30 minutes preceding the measurement.
- Under special circumstances, measuring blood pressure in the supine and standing positions may be indicated (see chapter 4).
- Measurement should begin after at least 5 minutes of rest.
- The appropriate cuff size must be used to ensure accurate measurement. The bladder within the cuff should encircle at least 80 percent of the arm. Many adults will require a large adult cuff.
- Measurements should be taken preferably with a mercury sphygmomanometer; otherwise, a recently calibrated aneroid manometer or a validated electronic device can be used.
- Both SBP and DBP should be recorded. The first appearance of sound (phase 1) is used to define SBP. The disappearance of sound (phase 5) is used to define DBP.
- Two or more readings separated by 2 minutes should be averaged. If the first two readings differ by more than 5 mm Hg, additional readings should be obtained and averaged.

Clinicians should explain to patients the meaning of their blood pressure readings and advise them of the need for periodic remeasurement. Table 3 provides followup recommendations based on the initial set of blood pressure measurements. More information regarding blood pressure measurement may be found in the American Heart Association's Recommendations for Human Blood Pressure Determination by Sphygmomanometers ^43^ and the American Society of Hypertension's Recommendations for Routine Blood Pressure Measurement by Indirect Cuff Sphygmomanometry. ^44^

Table 3 Recommendations for Follow Up Based on Initial Blood Pressure Measurements for Adults

Initial Blood Pressure (mm Hg)*
Systolic | Diastolic | Followup Recommended^†^
<130 | <85 | Recheck in 2 years
130–139 | 85–89 | Recheck in 1 year^‡^
140–159 | 90–99 | Confirm within 2 months^‡^
160–179 | 100–109 | Evaluate or refer to source of care within 1 month
≥180 | ≥110 | Evaluate or refer to source of care immediately or within 1 week depending on clinical situation

* If systolic and diastolic categories are different, follow recommendations for shorter time followup (e.g., 160/86 mm Hg should be evaluated or referred to source of care within 1 month).

† Modify the scheduling of followup according to reliable information about past blood pressure measurements, other cardiovascular risk factors, or target organ disease.

‡ Provide advice about lifestyle modifications (see chapter 3).

## Self-Measurement of Blood Pressure

Measurement of blood pressure outside the clinician's office may provide valuable information for the initial evaluation of patients with hypertension and for monitoring the response to treatment. Self-measurement has four general advantages: (1) distinguishing sustained hypertension from “white-coat hypertension,” a condition noted in patients whose blood pressure is consistently elevated in the physician's office or clinic but normal at other times; (2) assessing response to antihypertensive medication; (3) improving patient adherence to treatment; and (4) potentially reducing costs.^45^ The blood pressure of persons with hypertension tends to be higher when measured in the clinic than outside of the office.^46^ There is no universally agreed-on upper limit of normal home blood pressure, but readings of 135/85 mm Hg or greater should be considered elevated.^45,^ ^47,^ ^48^

### Choice of Monitors for Personal Use

Although the mercury sphygmomanometer is still the most accurate device for clinical use, it is generally not practical for home use. Therefore, either validated electronic devices or aneroid sphygmomanometers that have proven to be accurate according to standard testing^42,^ ^49,^ ^50^ are recommended for use along with appropriate-sized cuffs. Finger monitors are inaccurate.^51^ Periodically, the accuracy of the patient's device should be checked by comparing readings with simultaneously recorded auscultatory readings taken with a mercury device. Independent evaluations of the instruments available to patients are published from time to time.^52^

## Ambulatory Blood Pressure Monitoring

A variety of commercially available monitors, which are reliable, convenient, easy to use, and accurate, now are available.^49,^ ^50^ These monitors typically are programmed to take readings every 15 to 30 minutes throughout the day and night while patients go about their normal daily activities. The readings can then be downloaded onto a personal computer for analysis. Normal blood pressure values taken by ambulatory measurement (1) are lower than clinic readings while patients are awake (below 135/85 mm Hg); (2) are even lower while patients are asleep (below 120/75 mm Hg); and (3) provide measures of SBP and DBP load.^45,^ ^47^ In the majority of individuals, blood pressure falls by 10 to 20 percent during the night; this change is more closely related to patterns of sleep and wakefulness than to time of day, as illustrated by the blood pressure rhythm following the inverted cycle of activity in night-shift workers.^53^

Among persons with hypertension, an extensive and very consistent body of evidence indicates that ambulatory blood pressure correlates more closely than clinic blood pressure with a variety of measures of target organ damage such as left ventricular hypertrophy.^47^ Prospective data relating ambulatory blood pressure to prognosis are limited to two published studies, which suggest that, in patients in whom an elevated clinic pressure is the only abnormality, ambulatory monitoring may identify a group at relatively low risk of morbidity.^54–56^

Ambulatory blood pressure monitoring is most clinically helpful and most commonly used in patients with suspected “white-coat hypertension,” but it is also helpful in patients with apparent drug resistance, hypotensive symptoms with antihypertensive medications, episodic hypertension, and autonomic dysfunction.^45^ However, this procedure should not be used indiscriminately such as in the routine evaluation of patients with suspected hypertension.

## Evaluation

Evaluation of patients with documented hypertension has three objectives: (1) to identify known causes of high blood pressure; (2) to assess the presence or absence of target organ damage and cardiovascular disease, the extent of the disease, and the response to therapy; and (3) to identify other cardiovascular risk factors or concomitant disorders that may define prognosis and guide treatment. Data for evaluation are acquired through medical history, physical examination, laboratory tests, and other diagnostic procedures.

### Medical History

A medical history should include the following:

- known duration and levels of elevated blood pressure;
- patient history or symptoms of CHD, heart failure, cerebrovascular disease, peripheral vascular disease, renal disease, diabetes mellitus, dyslipidemia, other comorbid conditions, gout, or sexual dysfunction;
- family history of high blood pressure, premature CHD, stroke, diabetes, dyslipidemia, or renal disease;
- symptoms suggesting causes of hypertension;
- history of recent changes in weight, leisure-time physical activity, and smoking or other tobacco use;
- dietary assessment including intake of sodium, alcohol, saturated fat, and caffeine;
- history of all prescribed and over-the-counter medications, herbal remedies, and illicit drugs, some of which may raise blood pressure or interfere with the effectiveness of antihypertensive drugs (see chapter 4);
- results and adverse effects of previous antihypertensive therapy; and
- psychosocial and environmental factors (e.g., family situation, employment status and working conditions, educational level) that may influence hypertension control.

### Physical Examination

The initial physical examination should include the following:

- two or more blood pressure measurements separated by 2 minutes with the patient either supine or seated and after standing for at least 2 minutes in accordance with the recommended techniques mentioned earlier;
- verification in the contralateral arm (if values are different, the higher value should be used);
- measurement of height, weight, and waist circumference (see chapter 3);
- funduscopic examination for hypertensive retinopathy (i.e., arteriolar narrowing, focal arteriolar constrictions, arteriovenous crossing changes, hemorrhages and exudates,^57^ disc edema);
- examination of the neck for carotid bruits, distended veins, or an enlarged thyroid gland;
- examination of the heart for abnormalities in rate and rhythm, increased size, precordial heave, clicks, murmurs, and third and fourth heart sounds;
- examination of the lungs for rales and evidence for bronchospasm;
- examination of the abdomen for bruits, enlarged kidneys, masses, and abnormal aortic pulsation;
- examination of the extremities for diminished or absent peripheral arterial pulsations, bruits, and edema; and
- neurological assessment.

### Laboratory Tests and Other Diagnostic Procedures

Routine laboratory tests recommended before initiating therapy are tests to determine the presence of target organ damage and other risk factors. These routine tests include urinalysis, complete blood cell count, blood chemistry (potassium, sodium, creatinine, fasting glucose, total cholesterol, and high-density lipoprotein [HDL] cholesterol), and 12-lead electrocardiogram.

Optional tests include creatinine clearance, microalbuminuria, 24-hour urinary protein, blood calcium, uric acid, fasting triglycerides, low-density lipoprotein (LDL) cholesterol, glycosolated hemoglobin, thyroid-stimulating hormone, and limited echocardiography (see chapter 4) (to determine the presence of left ventricular hypertrophy). More complete assessment of cardiac anatomy and function by standard echocardiography, examination of structural alterations in arteries by ultrasonography, measurement of ankle/arm index,^58^ and plasma renin activity/urinary sodium determination may be useful in assessing cardiovascular status in selected patients.

## Identifiable Causes of Hypertension

Additional diagnostic procedures may be indicated to seek causes of hypertension, particularly in patients (1) whose age, history, physical examination, severity of hypertension, or initial laboratory findings suggest such causes; (2) whose blood pressures are responding poorly to drug therapy; (3) with well-controlled hypertension whose blood pressures begin to increase; (4) with stage 3 hypertension; and (5) with sudden onset of hypertension. For example, labile hypertension or paroxysms of hypertension accompanied by headache, palpitations, pallor, and perspiration suggest pheochromocytoma; abdominal bruits, particularly those that lateralize to the renal areas or have a diastolic component, suggest renovascular disease; abdominal or flank masses may be polycystic kidneys; delayed or absent femoral arterial pulses and decreased blood pressure in the lower extremities may indicate aortic coarctation; and truncal obesity with purple striae suggests Cushing syndrome. Examples of clues from the laboratory tests include unprovoked hypo-kalemia (primary aldosteronism), hypercalcemia (hyperparathyroidism), and elevated creatinine or abnormal urinalysis (renal parenchymal disease). Appropriate investigations should be conducted when there is a high index of suspicion of an identifiable cause.

### Genetics of Hypertension

Blood pressure levels are correlated among family members, a fact attributable to common genetic background, shared environment, or lifestyle habits.^59^ High blood pressure appears to be a complex trait that does not follow the classic Mendelian rules of inheritance attributable to a single gene locus; the currently documented exceptions are a few rare forms of hypertension, such as those related to a single mutation involving a chimeric 11-beta-hydroxylase/aldosterone synthase gene.^60^ High blood pressure appears to be a polygenic and multifactorial disorder in which the interaction of several genes with each other and with the environment is important.^61^ Potential candidate genes suggested by recent experimental data include those that affect various components of the renin-angiotensinaldosterone system, the kallikrein-kinin system, and the sympathetic nervous system.

## Risk Stratification

The risk of cardiovascular disease in patients with hypertension is determined not only by the level of blood pressure but also by the presence or absence of target organ damage or other risk factors such as smoking, dyslipidemia, and diabetes, as shown in Table 4. These factors independently modify the risk for subsequent cardiovascular disease, and their presence or absence is determined during the routine evaluation of patients with hypertension (i.e., history, physical examination, laboratory tests). Based on this assessment and the level of blood pressure, the patient's risk group can be determined, as shown in Table 5. This empiric classification stratifies patients with hypertension into risk groups for therapeutic decisions. The World Health Organization Expert Committee on Hypertension Control recently recommended a similar approach.^62^ Obesity and physical inactivity are also predictors of cardiovascular risk and interact with other risk factors, but they are of less significance in the selection of antihypertensive drugs.

Table 4 Components of Cardiovascular Risk Stratification in Patients with Hypertension*

Major Risk Factors
Smoking
Dyslipidemia
Diabetes mellitus
Age older than 60 years
Sex (men and postmenopausal women)
Family history of cardiovascular disease: women under age 65 or men under age 55
Target Organ Damage/Clinical Cardiovascular Disease
Heart diseases
- Left ventricular hypertrophy; - Angina/prior myocardial infarction; - Prior coronary revascularization; - Heart failure
Stroke or transient ischemic attack
Nephropathy
Peripheral arterial disease
Retinopathy

* See Table 5.

Table 5 Risk Stratification and Treatment*

Blood Pressure Stages (mm Hg) | Risk Group A (No Risk Factors No TOD/CCD)† | Risk Group B (At Least 1 Risk Factor, Not Including Diabetes; No TOD/CCD) | Risk Group C (TOD/CCD and/or Diabetes, With or Without Other Risk Factors)
High-normal (130–139/85–89) | Lifestyle modification | Lifestyle modification | Drug therapy^§^
Stage 1 (140–159/90–99) | Lifestyle modification (up to 12 months) | Lifestyle modification‡ (up to 6 months) | Drug therapy
Stages 2 and 3 (≥160/≥100) | Drug therapy | Drug therapy | Drug therapy
For example, a patient with diabetes and a blood pressure of 142/94 mm Hg plus left ventricular hypertrophy should be classified as having stage 1 hypertension with target organ disease (left ventricular hypertrophy) and with another major risk factor (diabetes). This patient would be categorized as Stage 1, Risk Group C, and recommended for immediate initiation of pharmacologic treatment.

* Lifestyle modification should be adjunctive therapy for all patients recommended for pharmacologic therapy.

† TOD/CCD indicates target organ disease/clinical cardiovascular disease (see Table 4).

‡ For patients with multiple risk factors, clinicians should consider drugs as initial therapy plus lifestyle modifications.

§ For those with heart failure, renal insufficiency, or diabetes.

### Risk Group A

Risk group A includes patients with high-normal blood pressure or stage 1, 2, or 3 hypertension who do not have clinical cardiovascular disease, target organ damage, or other risk factors. Persons with stage 1 hypertension in risk group A are candidates for a longer trial (up to 1 year) of vigorous lifestyle modification with vigilant blood pressure monitoring. If goal blood pressure is not achieved, pharmacologic therapy should be added. For those with stage 2 or stage 3 hypertension, drug therapy is warranted.

### Risk Group B

Risk group B includes patients with hypertension who do not have clinical cardiovascular disease or target organ damage but have one or more of the risk factors shown in Table 4 but not diabetes mellitus. This group contains the large majority of patients with high blood pressure. If multiple risk factors are present, clinicians should consider antihypertensive drugs as initial therapy. Lifestyle modification and management of reversible risk factors should be strongly recommended.

### Risk Group C

Risk group C includes patients with hypertension who have clinically manifest cardiovascular disease or target organ damage, as delineated in Table 4. It is the clinical opinion of the JNC VI executive committee that some patients who have high-normal blood pressure as well as renal insufficiency, heart failure, or diabetes mellitus should be considered for prompt pharmacologic therapy. Appropriate lifestyle modifications always should be recommended as adjunct treatment.

This classification (blood pressure stage and risk grouping) is directly linked to treatment and treatment goals as discussed in chapter 3. It provides practicing clinicians with a simple method of identifying risk strata for individual patients (by history, physical examination, and routine laboratory testing) as well as guidelines for treatment of those patients. From these findings, an assessment of absolute risk can be made. Tables, formulas, computer software programs, and World Wide Web sites are available for calculating cardiovascular risk in individual patients by means of data from epidemiologic studies.^63–66^

## Summary

- Table 2 provides a classification of blood pressure stages in adults. Stage 3 and stage 4 hypertension are now combined.
- Recommendations for detection, confirmation, and evaluation of high blood pressure remain consistent with those presented in the JNC V report.
- A new definition is proposed for normal blood pressure with self-monitoring and ambulatory blood pressure measurement.
- A discussion of genetics and a discussion of clinical clues to identifiable causes of hypertension have been added.
- New tables listing cardiovascular risk factors and describing risk stratification have been added.